# RESULTS

## Treatment Modality Recommendations in Clinical Practice Guidelines

The search of the National Guideline Clearinghouse using the word “wound” yielded 117 guidelines. After examination, it was determined that 11 guidelines provided usual care information on chronic wounds of interest.15–25 The other 106 guidelines did not deal with chronic wounds or mentioned wounds only peripherally. Table 3 summarizes information from these guidelines including the type of wound, guideline organization, year of publication, definition of wound, and treatment modality recommendations.

Table 3 Clinical practice guidelines (2 diabetic ulcers, 1 arterial ulcers, 1 venous ulcers, and 8 pressure ulcers) examined for the management of chronic wounds

Type of Wound | Guideline Organization (Year) | Definition of Chronic Wound | Recommendations | | | | | | Additional Recommendation
Type of Wound | Guideline Organization (Year) | Definition of Chronic Wound | Debridement | Wound Cleansing | Dressing | Pressure offloading | Infection Control | Surgical management | Additional Recommendation
Diabetic Ulcers
Foot Ulcerations | American college of foot and Ankle Surgeons 2000 | No Data | X | | X | X | X | X | - management of ischemia - medical management of comorbidities
Foot ulcers | New Zealand Guidelines Group 2003 | No Data | | | X | | X | | - close monitoring - prompt referral as appropriate
Arterial Ulcers
Lower-extremity arterial | Wound Ostomy and Continence Nurses Society (WOCN) 2002 | No Data | X | X | X | X | X | X | - nutrition - pain management - management of edema - adjunctive therapies - patients education
Venous Ulcers
Chronic leg ulcers (mostly venous) | New Zealand Guidelines Group 1999 | > 6 weeks | X | X | X | | X | X | - compression bandages
Pressure Ulcers
Pressure Ulcers | Wound, Ostomy, and Continence Nurses Society (WOCN) 2003 | No Data | X | X | X | X | X | X | - reduce friction and shear (keeping skin dry, using lift sheets or turning devices, overhead trapeze bars) - management of incontinence (bowel and bladder program; skin cleansing, skin barriers, etc) - nutrition management - educate patients caregivers and health care providers - adjunctive therapies
Stage I to IV Pressure Ulcers | Registered Nurses Association of Ontario (RNAO) 2002 | No Data | X | X | X | X | X | X | - management of nutritional needs - positioning - use static and dynamic support surfaces (e.g. special beds, mattresses, seat cushions that reduce pressure while sitting or lying) - referrals to interdisciplinary team members - pain management - education - adjunctive therapies
Pressure Ulcers | University of Iowa Gerontological Nursing Interventions Research Center 2002 | A pressure ulcer is any injury usually caused by unrelieved pressure that damages the skins and underlying tissue. | X | X | X | X | X | X | - management of tissue loads (pressure, friction, and shearing) - nutritional assessment and support
Pressure Ulcer | Singapore Ministry of Health 2001 | No Data | X | X | X | X | X | X | -Implementation of appropriate medical nutritional therapy -patient education -provision of effective pain alleviation and comfort measures
Pressure ulcers prevention and treatment (following spinal cord injury) | Paralyzed Veterans of America, 2000 | No Data | X | X | X | X | X | X | - adjunctive therapies (electrical stimulation) - continue assessment - preoperative and postoperative care - support surfaces and positioning (bed positioning, bed support surfaces, wheelchair positioning, wheelchair support surfaces)
Pressure ulcers | American Medical Directors Association (AMDA) 1999 | No Data | X | X | X | X | X | X
Pressure Ulcers | American Medical Directors Association (AMDA) 1996 | No Data | X | X | X | X | X | X | - preventive measure - bed and chair therapeutic positioning and tissue load management - management of comorbid conditions - education and rehabilitation of the patient/caregiver
Pressure Ulcers | Agency for Health Care Policy and Research (AHCPR) 1994 | No Data | X | X | X | X | X | X | - positioning techniques - support surfaces - controlling factors that impair healing - postoperative care - adjunctive therapies

Eight of the 11 guidelines covered pressure ulcers, 2 dealt with diabetic ulcers, and one discussed lower extremity arterial ulcers. None covered venous ulcers. The guidelines were published in the US, Canada, New Zealand, and Singapore by patient and professional organizations, and government agencies. These guidelines almost universally recommended all the basic treatment modalities: debridement, cleansing, dressing, antibiotics, and offloading. Some guidelines also recommended appropriate nutritional support. Since none of these guidelines dealt with venous ulcers, compression bandages were not mentioned.

## Recommendations in Surgical Textbooks

From more than 30 textbook titles examined, we identified only 5 recent editions of surgical textbooks that contained specific recommendations about chronic wound management.26–30 Table 4 summarizes the recommendations of the authors of these 5 textbook chapters. The descriptions of wound care in these chapters were uniformly terse, lacked specificity, and generally supported the basic treatment modalities recommended in the guidelines.

Table 4 Summaries of recommendations from selected surgical textbooks on treating chronic wounds

Textbook Author, Year | Recommendations to treat chronic wounds
[underlined: Surgical Infections] Fry DE 1995 | Diabetic foot infections: vascular assessment if debridement is necessary; culture specific antibiotics
[underlined: Principles of Surgery] 7^th^ ed., Schwartz SI 1999 | Chronic wounds: cleansing to reduce microbial load, debridement to remove damaged or necrotic tissue, irrigation with normal sterile saline, dressings
Surgery: Basic Science and Clinical Evidence Norton JA 2001 | Open wounds: debridement; moist sterile environment, dressing that prevents pressure (e.g., plain gauze and saline with or without antibiotic ointment)
[underlined: Textbook of Surgical Practice] 6^th^ ed., Rakel RE 2002 | Pressure ulcers: removing pressure and friction; surgical debridement depending on stage of ulcer; saline soaked gauze and exogenous local enzymes; moist environment; occlusive dressings
[underlined: Chronic Wound Management—the evidence for change] Mani R, ed. 2003 | Diabetic wounds: debridement, dressings, stimulation of wound healing Venous ulcer: dressings, application of bandages

## Usual Care in Randomized Controlled Trials

### Eligible Studies

We found 148 qualifying studies involving 12,233 patients. There were 43 diabetic ulcer trials with a total of 3,959 patients, 33 pressure ulcer trials with 1,593 patients, 66 venous ulcer trials with 6,335 patients, 5 trials with mixed type of ulcers including 315 patients, and one arterial ischemic ulcer trial with 31 patients. The details of these studies are described in the evidence tables (appendices B – F).

### Study Characteristics

Table 5 summarizes the characteristics of the included studies. The average number of patients enrolled in these studies was less than 100. Among the diabetic ulcer trials, the largest study was a multi-center trial that included 922 patients. Seven other diabetic ulcer studies enrolled more than 100 patients each, and none recruited more than 276 patients. One RCT on pressure ulcers provided only the number of ulcers (28 ulcers) without the corresponding number of patients. Seventeen venous ulcer trials had sample sizes larger than 100 patients but only one reported a sample more than 300 patients. More than half of the diabetic ulcer studies as well as almost half of the pressure ulcer trials were conducted in the US. Among venous ulcer RCTs, almost one-third were conducted in UK and one-fifth in the US. Multi-center trials involving more than one country were rare; these include one pressure ulcer and 6 venous ulcer trials. The average age of patients in diabetic ulcer studies was less than 60 years while in pressure ulcer and venous ulcer trials patients enrolled had a mean age over 66 years old. Males were predominant in diabetic ulcer studies and comprised almost 50% of pressure ulcer and venous ulcer trials. Half of the studies on diabetic ulcer pertained to ambulatory patients. More than 70% of the venous ulcer trials were conducted in an outpatient setting. The majority of pressure ulcer studies were performed in hospitalized patients or nursing home residents.

Table 5 Characteristics of RCTs of diabetic, pressure and venous ulcers

Characteristics of included studies | | Type of ulcers
Diabetic N=43 | Pressure N=33 | | Venous N=66
Sample size (mean, range) | 97 (6–922) | 51 (7–207) | 97 (9–500)
Country
USA n (%) | 22 (52) | 16 (48) | 14 (21)
UK n (%) | 2 (5) | 5 (15) | 19^*^ (29)
Italy n (%) | 7 (17) | 0 (0) | 7^*^ (11)
other^**^ n (%) | 12 (29) | 12 (36) | 26 (39)
not specified n (%) | 0 (0) | 0 (0) | 1 (2)
Average age (mean, range) | 59 (50–73) | 70 (44–88) | 66 (50–76)
Average %male (mean, range) | 70 (42–93) | 47 (13–100) | 45 (16–85)
Setting
outpatient n (%) | 23 (53) | 7 (21) | 49 (74)
inpatient n (%) | 14 (33) | 23 (70) | 9 (14)
mixed n (%) | 3 (7) | 3 (9) | 3 (5)
not specified n (%) | 3 (7) | 0 (0) | 5 (8)
Ulcer duration
>30 days n (%) | 13 (30) | 7 (21) | 43 (65)
Mixed n (%) | 13 (30) | 11 (33) | 15 (23)
not specified n (%) | 17 (40) | 15 (45) | 8 (12)

* One study recruited patients both from UK and Italy

** None of the countries in this category reported more than 3 RCTs. Countries in this category include: Australia, India, Japan, Mexico, Thailand, and Western and Eastern European countries

Forty percent of the diabetic ulcer articles and 45% of the pressure ulcer trials did not specify ulcer duration. One-third of pressure ulcer studies reported ulcer duration either longer or shorter than 30 days. Less than one-third of the diabetic ulcer studies mentioned explicitly that ulcer duration was more than 30 days. Among venous ulcer RCTs, 65% clearly studied chronic wounds defined as an ulcer duration longer than 30 days.

## Treatment Modalities for Usual Care

Table 6 and Figure 1–4 summarize the frequency of reported uses of various treatment modalities for diabetic, pressure, and venous ulcers. About 80% of the diabetic ulcer and more than one-third of pressure ulcer trials reported surgical debridement. Non-surgical debridement was reported in only one out of 43 diabetic ulcer studies. Twelve (18%) venous ulcer RCTs mentioned surgical debridement. Non-surgical debridement was reported in less than 10% of pressure ulcer and venous ulcer studies. About 30% of diabetic ulcer RCTs reported on cleansing while more than half of the pressure ulcer and venous ulcer studies reported cleansing as part of the usual care. Compression was described in 6 (14%) of diabetic ulcer studies while it was not mentioned at all for pressure ulcers. Compression was the most popular (83%) modality for venous ulcers. Thirty-five percent of diabetic ulcer studies described the use of antibiotics to treat wound infections in their trial protocol. Mention of antibiotics was much less common in pressure ulcer (12%) and venous ulcer (15%) trials. Descriptions of antibiotic use generally do not include the route of administration or the specific drugs. Finally, usual care included pressure offloading in most (79%) diabetic ulcer trials, in almost half (48%) of the pressure ulcer trials, but in only 3 (5%) of venous ulcer trials.

Table 6 Number of RCTs reporting various treatment modalities as part of usual care for diabetic, pressure, and venous ulcers

Treatment modality | | Type of ulcers
Diabetic n (%) N=43 | Pressure n (%) N=33 | | Venous n (%) N=66
Surgical debridement | 34 (79) | 12 (36) | 12 (18)
Non-surgical debridement | 1 (2) | 3 (9) | 6 (9)
Cleansing | 13 (30) | 17 (52) | 34 (52)
Dressing^*^ | 40 (93) | 32 (97) | 57 (86)
Compression | 6 (14) | 0 (0) | 55 (83)
Antibiotics | 15 (35) | 4 (12) | 10 (15)
Offloading | 34 (79) | 16 (48) | 3 (5)

* Detailed dressing information appears in Table 7.

Figure 1 Frequency of reported wound care modalities in control groups of RCT Number of studies: 43 diabetic, 33 pressure, 66 venous

reported wound care modalities in control groups of RCT Number of studies: 43 diabetic, 33 pressure, 66 venous

Figure 2 Frequency of reported wound care modalities in control groups of 43 RCTs of diabetic ulcers

Figure 2. Frequency of reported wound care modalities in control groups of 43 RCTs of diabetic

Figure 3 Frequency of reported wound care modalities in control groups of 33 RCTs of pressure ulcers

Figure 3. Frequency of reported wound care modalities in control groups of 33 RCTs of pressure

Figure 4 Frequency of reported wound care modalities in control groups of 66 RCTs of venous ulcers

Figure 4. Frequency of reported wound care modalities in control groups of 66 RCTs of venous

Types of dressings were specifically delineated for each wound type and then grouped into 3 categories (Table 7 and Figure 5): 1) non-occlusive, 2) semi-occlusive, and 3) occlusive. There was significant variability in the type of wound dressings employed in the control groups of the diabetic, venous, and pressure wounds. In the diabetic ulcer trials, 51% used saline wet-to-dry dressings but only 14% used hydrocolloid dressings in the control group. Hydrocolloid and saline wet-to-dry dressings were used equally at about 40% in pressure ulcer trials. Unlike the control group in diabetic ulcer trials, saline wet-to-dry was an infrequent dressing type for venous ulcers (3 trials), while in 16 other trials additional forms of non/semi-occlusive dressings were used--dry gauze, Vaseline gauze, and ointment. The Unna boot, a combination of a rigid compression device and topical medication for the ulcer, was used in 10 studies. An occlusive type of dressing, usually hydrocolloid, was the most frequently employed dressing in venous ulcer trials—25 studies.

Table 7 Number of RCTs reporting specific types of wound dressings as part of usual care for diabetic, pressure, and venous ulcers

Wound dressing | | Types of wounds
Diabetic n (%) N=43 | Pressure n (%) N=33 | | Venous n (%) N=66
Non-occlusive
Ointment/Cream | 1 (2)^a^ | 2 (6)^c^ | 6 (9)^d,e^
Dry gauze | 2 (5) | 3 (9) | 10 (15)^d,g,h^
Semi-Occlusive
Saline wet-to-dry | 22 (51)^a^ | 13 (39)^b^ | 3 (5)
Wet dressing | 0 (0) | 0 (0) | 2 (3)^e^
Paraffin gauze | 2 (5) | 1 (3)^c^ | 1 (2)^f^
Vaseline gauze | 1 (2) | 0 (0) | 4 (6)
Occlusive
Unna boot | 0 (0) | 0 (0) | 10 (15)^h^
Hydrocolloid | 6 (14) | 14 (42)^b^ | 25 (40)^f,g,h^
Dressing not clearly specified | 7 (16) | 1 (3) | 5 (8)
No dressing reported | 3 (7) | 1 (3) | 8 (12)

a One diabetic study used both cream and saline wet-to-dry gauze

b One pressure study used either saline wet-to-dry gauze or hydrocolloid

c One pressure study used both ointment and paraffin gauze

d One venous study used cream, dry gauze

e One venous study used cream, wet dressing

f One venous study used paraffin gauze, hydrocolloid

g One venous study used dry gauze, hydrocolloid

h One venous study used dry gauze, hydrocolloid, Unna boot

Figure 5 Distribution of specific wound dressings in various types of ulcers

Number of trials: 43 diabetic, 33 pressure, 66 venous ulcer trials

Figure 5. Distribution of specific wound dressings in various types of ulcers Number of trials: 43 diabetic, 33 pressure, 66 venous ulcer trials0102030405060Ointment/

## Frequency of Dressing Changes

Twenty-three of the 43 diabetic ulcer trials (53%) reported the frequency of dressing changes. In most of these studies (17/23) dressings were changed once or twice daily. Dressings were changed every 2 days in 5 studies and twice weekly in one study. Among the 15 pressure ulcer studies that described the frequency of dressing changes, 10 reported once or twice daily, 2 every other day, and 3 once or twice per week. In the venous ulcer studies, dressing changes of once or twice weekly was mentioned in the 28 out of the 38 RCTs that provided this information. Venous ulcer dressings were changed every 2 days in 7 trials, and once or twice per day in only 3 trials. Forty-seven percent of diabetic ulcer trials, 55% of pressure ulcer trials, and 42% of venous ulcer trials did not report the frequency of dressing changes.

## Conformance of RCTs to Recommendations in the FDA Draft Guidance Document

We selected the 20 largest trials from each of the diabetic, venous, and pressure ulcer categories and assessed the frequency with which these studies conformed to the recommendations in the FDA Draft Guidance Document. The results are summarized in Table 8 and Figure 6. Evidence tables for these studies are in appendices G – I.

Table 8 Frequency of studies conforming to recommendations proposed in the FDA Draft Guidance for Industry (based on 20 selected articles for each wound type)

FDA Draft Guidance Document Recommendations | | Type of ulcers
Diabetic n (%) N=20 | Pressure n (%) N=20 | | Venous n (%) N=20
Outcome assessment
Partial wound closure | 9 (45) | 0 (0) | 5 (25)
Complete wound closure | 19 (95) | 17 (85) | 18 (90)
Partial or complete (unclear) | 1 (5) | 3 (15) | 1 (5)
3 months post-wound closure assessment | 8 (40) | 0 (0) | 3 (15)
Wound size pre- & post-debridement | 1 (5) | 0 (0) | 1 (5)
Method of assessing wound size
Photographic/digital imaging | 5 (25) | 12 (60) | 7 (35)
Planimetry (computerized or mechanical) | 7 (35) | 3 (15) | 10 (50)
Not specified | 8 (40) | 5 (25) | 5 (25)
Antimicrobial treatment
Pre- versus during study | 0 (0) | 3 (15) | 3 (15)
Systemic versus topical | 0 (0) | 3 (15) | 2 (10)
Provider
Health care provider | 5 (25) | 3 (15) | 10 (50)
Patient | 1 (5) | 1 (5) | 0 (0)
Both | 4 (20) | 1 (5) | 0 (0)
Not specified | 10 (50) | 15 (75) | 10 (50)
Maximum treatment duration
1 – 3 weeks | 0 (0) | 1 (5) | 0 (0)
4 weeks | 0 (0) | 5 (25) | 1 (5)
5 – 7 weeks | 3 (15) | 2 (10) | 0 (0)
8 weeks | 1 (5) | 6 (30) | 0 (0)
9 – 11 weeks | 1 (5) | 3 (15) | 0 (0)
12 weeks | 8 (40) | 2 (10) | 4 (20)
13 – 23 weeks | 4 (20) | 0 (0) | 1 (5)
24 weeks | 0 (0) | 0 (0) | 5 (25)
25 – 52 weeks | 3 (15) | 0 (0) | 9 (45)
not specified | 0 (0) | 1 (5) | 0 (0)

Figure 6 Frequency of reported data conforming to FDA Draft Guidance Document

20 selected largest studies each of diabetic, pressure, and venous wounds

Figure 6. Frequency of reported data conforming to FDA Draft Guidance Document 20 selected largest studies each of diabetic, pressure,

Among the outcomes that the FDA suggested in its Draft Guidance Document, partial wound closure was included as an outcome in 9 (45%) diabetic ulcer and 5 (25%) venous ulcer trials. Complete wound closure was reported in 19 (95%) of the diabetes ulcer, 17 (85%) of the pressure ulcer, and 18 (90%) of the venous ulcer studies we sampled. Post-closure assessment of the wound after 3 months was included in 8 (40%) of the diabetic ulcer trials and in 3 (15%) of the venous ulcer trials in our sample. One diabetic ulcer RCT reported wound size before and after debridement and one venous ulcer RCT reported pre-debridement wound size. Antimicrobial treatment was described only in pressure ulcer and in venous ulcer trials in our sample. Assessment of wound size using photographic or digital imaging techniques was reported in 25% of diabetic ulcer, 60% of pressure ulcer, and 35% of venous ulcer studies.

In the majority of the studies, the care provider was not specified. Nonetheless, a health care provider was described in 5 (25%) diabetic ulcer, 3 (15%) pressure ulcer, and 10 (50%) venous ulcer trials of the sample. In 3 papers – one diabetic ulcer and 2 pressure ulcer – the patient was the only care provider mentioned. The length of the diabetic ulcer trials typically lasted about 12 weeks, while pressure ulcer trials typically lasted 8 weeks. None of the pressure ulcer trials reported treatment duration of more than 12 weeks, whereas venous ulcers were invariably treated for a longer period. Almost half of the venous ulcer trials reported 24-week maximum treatment duration. Only 2 venous ulcer trials had treatment duration of less than 12 weeks.