# METHODS

We performed a systematic review of the literature to extract information about the background care given to patients in the control group in randomized controlled trials (RCTs) as a proxy for standard of care. Analyses were restricted to RCTs because these studies generally have the most complete description of the background care information compared with other less rigorous study designs. In this report, treatment modalities prescribed in the control groups will be referred to as “usual care.” Clinical practice guidelines and selected surgical textbooks were reviewed for recommendations from authoritative bodies or opinion leaders on chronic wound management to identify major chronic wound treatment modalities and to complement our review of RCTs.

## Literature Search

We searched clinical practice guidelines, surgical textbooks, and RCTs in June and July of 2004. Searches for guidelines and textbooks were not meant to be exhaustive. They were intended to provide guidance on the range of treatment modalities generally recommended. We searched for clinical trial articles published since 1997, because the goal of this report is to summarize the usual care practice in recent clinical trials of chronic wound treatments.

## Clinical Practice Guidelines

We searched the National Guidelines Clearinghouse (www.ngc.gov) and MEDLINE for clinical practice guidelines on the management of chronic wounds and these were examined for information pertaining to standard of care. In addition, our surgical consultant contacted several major surgical societies in the US for potential guidelines not included in the Clearinghouse but found none.

## Surgical Textbooks

We examined chapters on wound care in a convenient sample of textbooks available on the surgical textbook shelves at the Tufts and Harvard medical school libraries for specific recommendations about usual care for chronic wounds.

## Randomized Controlled Trials

We searched for English-language studies in MEDLINE, CINAHL, and the Cochrane Controlled Trials Registry databases on June 30 of 2004. Following consultation with AHRQ and CMS, we limited our literature search to articles published since 1997, which was the publication year of the first UK NHS chronic wounds TAs. A total of 2,762 unique citations were identified. After screening titles and abstracts, 277 articles were retrieved for review.

## Inclusion Criteria

As a set of minimum inclusion criteria, we accepted English language RCTs evaluating treatments of chronic wounds with any number of human subjects. In general, chronic wounds are defined as wounds that do not heal completely after receiving standard medical treatment for 30 days. Because the focus of this report is not on the evaluation of clinical outcomes, there is less concern about the potential bias that may be introduced by including studies that did not clearly state the duration of wound. Therefore, we accepted RCTs that included mixed duration ulcers in which some of the ulcers might have received standard medical treatment for less than 30 days, as well as studies that did not clearly specify wound duration. In our judgment most of the ulcers were likely to have been treated for at least 30 days.

## Types of Chronic Wounds

In this report we considered the following types of chronic wounds: ischemic ulcers due to peripheral arterial occlusive disease, ulcers due to venous disease, diabetic foot ulcers (usually neurotrophic), and decubitus ulcers due to pressure. Ulcers secondary to ischemic arterial occlusive disease usually undergo revascularization to correct inadequate regional perfusion and in general are not the subject of RCTs. An exception to this is the concomitant use of hyperbaric oxygen, a form of treatment outside the realm of usual care. Because the focus of this report is not on the outcomes of treatments, we accepted trials of any duration of treatment. For completeness, studies that included different types of ulcers and did not provide clear delineation of subgroups of wound types are reported in a separate table of mixed wounds. However, this group of studies was not analyzed because of the uncertainty of the wound category and duration.

## Usual Care Treatment Modalities

Specific treatments in the control arms of the RCTs were categorized into one of the following 6 treatment modalities: debridement, cleansing, dressing, compression bandage, antibiotics, and pressure offloading. Debridement methods were further categorized into surgical and non-surgical (i.e., enzymatic) debridement. In addition, dressings were categorized into non-occlusive, semi-occlusive, and occlusive. Non-occlusive dressing includes ointment/cream and dry gauze. Semi-occlusive dressing includes saline wet-to-dry, wet dressing, paraffin gauze, and Vaseline gauze. Occlusive dressings include Unna boot and various hydrocolloids. Management of chronic wounds should include treating the underlying condition and co-morbidities, which might include optimizing blood glucose control in patients with diabetic ulcers, ensuring adequate nutrition status in debilitated patients, revascularization in patients with ischemic artery disease, and pain management. While these treatments modalities are important aspects of total patient management, they are not directed at the treatment of the wound and are not considered in this report.

## Study Design

RCTs, non-randomized controlled comparison studies, and cohort studies were initially included in the analysis. We found after preliminary assessment of the literature that 84% of the retrieved studies were RCTs. Excluding the small number of non-randomized studies would have little impact on the results. Focusing on RCTs, as they most likely represent the highest quality of evidence, will improve the reliability of the conclusions. Therefore, after consultation with CMS and AHRQ, only RCTs were included in this report.

We also included RCTs without a clear control group (e.g., RCTs that compare one type of dressing with another type of dressing, or trials that compare one type of compression bandage with another type of compression bandage). In that case, treatments in all arms of the RCT were extracted, and the usual care for the modality in comparison consisted of more than one treatment (e.g., 2 different types of bandages for compression).

## Analysis of the Literature

The review of RCTs focused on determining the frequency of specific treatment modalities that had been used in the control arms for each of the 4 different types of wounds. We also sought to describe the characteristics of the RCTs by wound type. Because authors often do not completely report information about the trial, the lack of description of treatment modalities in an article should not be interpreted as a lack of use of a specific treatment modality. For example, some authors might have taken certain basic treatment modalities for granted (e.g., antibiotics treatment for infected wounds). Therefore, the information on the frequency of various treatment modalities as a proxy of standard of care should be interpreted accordingly.

## Conformance of RCTs to Recommendations in the FDA Draft Guidance Document for the Industry

The FDA Draft Guidance Document for the Industry was used as another source of recommendations for usual care in clinical trials testing wound care products. This document also discussed certain design issues that should be addressed in future trials. We reviewed the FDA draft guidance document for the industry to identify recommended elements of outcomes assessment and trial design in the evaluation of wound care products.

For outcomes assessment, these elements include: assessment of partial or complete wound closures, and measurement of wound size pre- and post-debridement. According to the FDA document, prospectively defined partial wound healing (including wound size change) may be used as supportive evidence for the beneficial biological activities of a product or procedure. However, this is not an acceptable surrogate for complete wound healing. An exception is partial wound healing that facilitates surgical closure. Assessment of the wound size and infection status should be conducted after surgical debridement. Enzymatic debridement agents should be avoided because these are applied as topical agents and may confound the results of wound product trials. Measurement of wound size should be standardized with photographic imaging procedures at each clinic visit.

Systemic antibiotic therapy may be necessary during the course of the trial because wounds do not heal in the presence of infection. A trial should document the antimicrobial usage in the study population before and during the trial and the FDA Draft Guidance Document recommends that the study protocol discuss whether the study treatment should be continued in the event of an infection.

In consultation with AHRQ and CMS, we selected approximately 20 of the largest RCTs from each of the diabetic ulcer, pressure ulcer, and venous ulcer categories for additional analyses according to several outcomes recommended in the FDA Draft Guidance Document. The frequency of reporting of the following items were noted:

- partial wound closure
- complete wound closure
- 2 months post-wound closure assessment
- wound size pre- and post-debridement
- photographic imaging methods to assess wound size

In addition, CMS also requested an analysis of the reporting of wound care provider.