# BACKGROUND

The Center for Medicare and Medicaid Services (CMS) requested a technology assessment (TA) report from the Agency for Healthcare Research and Quality (AHRQ) summarizing the usual care for chronic wound management in patients presenting with decubitus ulcers due to pressure, or foot or leg ulcers due to diabetes, or arterial or venous disease. This report will be used to inform a meeting of the Medicare Coverage Advisory Committee (MCAC) in March 2005. This committee will use the information in this report, in conjunction with other data, to deliberate on the trial designs that will be needed to support the development of sufficient evidence to determine the appropriate treatment of chronic wounds. This report is not intended to support the development of clinical practice guidelines. In this report, chronic wounds are defined as wounds that do not heal completely after receiving standard medical treatment for 30 days.

The UK NHS R&D Health Technology Assessment Programme published a set of comprehensive TA reports on the management of chronic wounds between 1997–2000.^1–4^ The NHS TA reports were systematic reviews of treatments for chronic wounds assessing the efficacy of mechanical and non-mechanical debridement, dressings and topical agents, antimicrobial agents, beds, compression, laser therapy, therapeutic ultrasound, electrotherapy, and electromagnetic therapy. These TA reports reviewed the comparative efficacy of treatment modalities but they did not make specific recommendations for standard of care. Table 1 summarizes the interventions assessed for various types of chronic wounds in these TA reports. The purpose of the NHS TA was to provide a comprehensive review of the evidence of different wound care interventions. The purpose of the current report (described in further detail below) is to look at the trial design, and specifically the elements of usual care, in recent clinical trials of wound care interventions.

Table 1 Summary of the UK NHS Technology Assessment Reports on Chronic Wounds

Technology assessed | Number of studies, design, wound type | Date search completed | Conclusions
Dressings and topical agents used in arterial and venous ulcers
Surgical wounds healing by secondary intervention | 5 studies | October 1997 | There is little evidence to indicate which dressings or topical agents are the most effective in the treatment of chronic wounds. There is evidence that hydrocolloid dressings are better than wet-to –dry dressings for the treatment of pressure scores. In the treatment of venous ulcers, low adherent dressings are as effective as hydrocolloid dressings beneath compression bandaging
Pressure sores | 28 trials –31 comparisons of treatments | October 1997
Leg ulcers Compared Hydrocolloids with traditional dressings | 60 studies –evaluated dressings or topical agents in arterial and venous ulcers - 9 trials –compared with Hydrocolloids - 2 trials compared hyaluronic acid with control - 4 trials compared biological dressings with traditional therapies - 2 trials compared dressings with topical preparations - 11 trials compared dressing with dressing | October 1997
Antimicrobials
Antimicrobials | 30 studies (25 RCTs) -9 evaluations of systemic antimicrobials -21 evaluations of topical agents. | January 2000 | There is no existing evidence to support the use of systemic agents for chronic wound healing. Even with interventions that appear to be promising, existing trials are general small and many have other methodological problems. The methods of measuring outcomes being poorly developed, with little use of quality-of –life measures and widespread use of unblinded, subjective outcome measures. Several topical agents may be helpful, but further research is required.
Diabetic foot ulceration
Prevention modalities | 10 trials - footwear (2) - hosiery (1) - education (5) - screening and foot protection (1) - podiatry (1) | End of 1998 | Much uncertainty remains over the most effective interventions for the prevention and treatment of diabetic foot ulcers. Certain treatments (e.g. growth factors and offloading techniques such as total contact casting) show promise but need further, more rigorous evaluation.
Treatment modalities | 29 trials - footwear (1) - skin replacement (2) - hyperbaric oxygen (2) - ketanserin (3) - Prostaglandins (3) - growth factors (5) - dressings and topical applications (9) - debridement (2) - antibiotics (2) | End of 1998
Bed, mattresses, and cushions for pressure score prevention and treatment
Bed, mattresses, and cushions for pressure score prevention and treatment | 45 RCTs -3 different operating –table surfaces -6 evaluated different surfaces in intensive care units -7 evaluated to orthopedic patients -2 evaluated cushions -1 evaluated the use of sheepskins -2 looked at turning beds/kinetic therapy The remaining evaluated different mattresses, mattress overlays and beds | April 2000 | Foam alternatives to the standard hospital foam mattress can reduce the incidence of pressure sores in people at risk, as can pressure-relieving overlays on the operating table. One study suggests that air-fluidised therapy may increase pressure score healing rates. There is insufficient evidence to draw conclusions about the value of seat cushions, various CLP devices (either overlays, mattresses or replacement beds) and sheepskin as pressure sore prevention strategies
Compression for leg ulcers
Compression bandages | 24 Trials (reporting 26 comparisons) -2 prevention -24 treatment strategies | December 1999 | Compression is more effective in healing venous leg ulcers than is no compression, and multi-layered high compression is more effective than single-layer compression. High-compression hosiery was more effective than moderate compression in preventing ulcer recurrence
Laser therapy, therapeutic ultrasound, electrotherapy and electromagnetic therapy
Low-level Laser therapy (for venous leg ulcers) | 4 RCTs | December 1999 | There is insufficient reliable evidence to draw conclusions about the contribution of laser therapy, therapeutic ultrasound, electrotherapy and electromagnetic therapy to chronic wound healing.
Therapeutic ultrasound (for pressure sores and venous leg ulcers) | 10 RCTs - 7 RCTs for venous leg ulcers - 3 RCTs for pressure sores | December 1999 | There is insufficient reliable evidence to draw conclusions about the contribution of laser therapy, therapeutic ultrasound, electrotherapy and electromagnetic therapy to chronic wound healing.
Electrotherapy (for ischaemic and diabetic ulcers, and chronic wounds generally) | 14 RCTs - 2 RCTs for chronic wounds - 5 trials for ischaemic ulcers -1 study for diabetic ulcers -3 RCTs for pressure sores -3 trials for venous ulcers | December 1999 | There is insufficient reliable evidence to draw conclusions about the contribution of laser therapy, therapeutic ultrasound, electrotherapy and electromagnetic therapy to chronic wound healing.
Electromagnetic therapy | 5 studies - 3 RCTs with a total of 92 patients for the treatment of venous leg ulcers - 2 trials with a total 55 patients for the treatment of pressure sores | December 1999 | There is insufficient reliable evidence to draw conclusions about the contribution of laser therapy, therapeutic ultrasound, electrotherapy and electromagnetic therapy to chronic wound healing.

The FDA published a draft document in 2000 providing guidance on study designs and related issues for the industry developing products for treatment of chronic cutaneous ulcers and burn wounds.5 Relevant to the present TA report, the draft document provided recommendations on the outcome measures and trial designs. However, the draft FDA document represents the view of only one government agency and it was not intended to provide recommendations for routine clinical practice.

The purpose of this report is to review the studies of chronic wound treatments published in the clinical trial literature since the NHS TA reports. Specifically, the questions to be addressed for arterial, decubitus, diabetic, and venous ulcers are:

1. What is the usual care given to patients in clinical trials of chronic wound management?
2. What are the common elements of wound care across different types of wounds? Include when possible information on: type of treatment, frequency of treatment, duration of treatment, setting, providers (caregivers), age range. Summarize information from 20 largest studies for diabetic, pressure, and venous ulcers according to recommendations in the FDA Draft Guidance Document for the Industry.
3. What treatment modalities are unique for each type of chronic wounds?
4. Analyze and discuss the evidence and rationale for each of the treatment modalities used in usual care.

In this TA, CMS is interested in understanding the various specific treatment modalities that are currently used as usual care for healing of chronic wounds (e.g., compression bandaging improves venous ulcer healing compared with no bandaging). CMS is not interested in learning about specific comparative efficacy between specific treatment modalities (e.g., one type of bandage compare with another type), as performed in the NHS TAs.

## Rationale for Various Treatment Modalities for Chronic Wounds

The etiology of a chronic wound (ulcer) can generally be determined by the patient’s history and physical examination. Some ulcers occur in patients with multiple conditions (e.g., a patient with diabetes and ischemic arterial disease) and it may be necessary to receive definitive treatment for one condition before the treatment for the other can become effective. Certain diagnostic tests may be useful to confirm the etiology of the ulcer (e.g., measurement of the arterial/brachial index to diagnose ischemic arterial disease versus a neurotrophic cause; blood glucose or glycosylated hemoglobin to diagnose diabetes mellitus).

The depth of the wound determines the overall type of process by which healing takes place. Partial Thickness wounds involve the epidermal and dermal layers only and heal by regeneration, whereby the same tissue replaces the tissue that has been lost. Epithelial cells migrate into the wound from the wound margin. Full Thickness wounds are devoid of both the epidermis and dermis and reach the level of subcutaneous tissue or muscle. At this level wound repair must proceed by granulation, contraction, and re-epithelialization.

## The Biology of Wound Healing

A chronic wound is a wound "that has failed to proceed through an orderly and timely series of events to produce a durable, structural and cosmetic closure."2 Obviously, this definition depends upon a timeline whereby the normal or acute wound is usually closed by four weeks. The various types of dressing treatments for chronic wounds can best be understood by first relating the dressing types to the phase during which they might act. The biological phases of wound healing have traditionally been divided into 3 progressive segments6:

- inflammatory phase
- proliferative phase
- maturational phase

During the inflammatory phase platelets play a central role in wound healing, initially through stabilization of the wound by clot formation. Platelets then activate the complement cascade, and the released cytokines (specific growth factors) attract and stimulate cells essential to wound healing. This process attracts the chief scavenger cell, the neutrophil, to the wound, thus initiating autogenous debridement. In contrast to the normal progression of wound healing to the next phase, chronic wounds appear to be stuck in the inflammatory phase.

In the second phase of wound healing, the proliferative phase, another critical cell, the macrophage, subsequently orchestrates several important processes including: 1) further wound debridement, 2) migration of fibroblasts into the wound with subsequent collagen synthesis, 3) angiogenesis, and 4) formation of granulation tissue from the collagen and new blood vessels in the wound. Methods for stimulating angiogenesis have been the focus of more recent wound therapies because new capillary growth provides wound nutrients and helps to develop the granulation tissue bed. In the latter steps of the proliferative phase, the wound contracts due to myofibroblasts while epithelial cells from the margin of the wound start to migrate across the wound surface.

The third phase of wound healing, the maturational phase, is associated with further formation of granulation tissue and progressive epithelialization from the wound margin so that the wound surface becomes totally covered. This process involves a symphony of cytokines, such as platelet derived growth factor (PDGF), insulin-like growth factor (ILGF) and epithelial growth factor (EGF). During this phase the wound is remodeled by simultaneous synthesis and breakdown of collagen. Collagen becomes organized into bundles as the tensile strength of the wound is increased.

## Clinical Considerations

Table 2 summarizes the major types of wound dressings, their mechanism of action, wound healing phase affected, and specific examples of that dressing type. Wound dressings serve a number of purposes including preventing physical and bacterial contamination of the wound, while maintaining the viability of the cells both within the wound and at the wound margin. This is accomplished by providing a moist and warm wound environment and facilitating migration of cells at the wound margin to provide wound coverage.

Table 2 Mechanisms of Various Wound Treatments

Dressing Classification | Mechanism | Wound Healing Phase Affected | Examples
Non-occlusive | Anti-infective
Antibacterials (topical or systemic) | Control or eradicate infection to permit healing | Inflammatory | Neosporin, Betadine, Silvadene, systemic antibiotics
| Debridement
Debriding agents/methods | Remove necrotic tissue which interferes with healing response | Inflammatory | Saline “wet to dry” Accuzyme^®^, Panafil^®^
Semi-occlusive/occlusive
Films Hydrocolloids Hydrogels Alginates Foams | Provide moist and warm wound environment Absorb exudate | Inflammatory & Proliferative | Opsite^®^, Tegaderm^®^, Duo Derm^®^, Tegagel^®^, Sorbsan^®^, Allevyn^®^
Biological treatments (mostly experimental)
Living human dermal equivalent | Wound coverage – stimulate growth factors | Proliferative | Dermagraft^®^ - neonatal foreskin derived fibroblast on a matrix Appligraft^®^ - cultured neonatal foreskin fibroblasts and keratinocytes
Growth Factors | Promote recruitment and proliferation of cells | Proliferative | Regranex^®^
Platelet Concentrates | Stimulate the activation of key wound healing mechanism | Proliferative
Stem Cells | Multiple

In addition to the type of dressing used in treating chronic wounds, several common principles apply to the management of most chronic wounds: 1) removal of dead and devitalized tissue which provides a nidus for bacterial infection (not colonization), 2) aggressive antibiotic treatment of peri-wound and wound infections, 3) mechanical measures which may favorably alter local hemodynamics or ameliorate adverse physical forces, and 4) optimization of general nutrition.

Most wounds are colonized by bacteria. Debridement of necrotic tissue is generally carried out to reduce the potential for delayed wound healing by gross active bacterial infection that produces persistent inflammation. For example, diabetic ulcers typically undergo sharp debridement of eschar and hypertrophic callus by scalpel, which has been shown to be an independent contributing factor to healing of diabetic ulcers.7 Antibiotics are employed for obvious cellulitis or gross infection of the wound. Finally, mechanical measures are essential to counteract regional contributory factors adverse to wound healing. These include “pressure offloading" for diabetic foot ulcers and elastic compression for chronic venous ulcers.

The diabetic foot develops not only a gross sensory loss but also an impairment of proprioception. By redistributing the weight off the bony prominences (i.e., metatarsal heads) – offloading – chronic excessive pressure is reduced on these sites.7 Offloading minimizes callus formation and subcallosal hemorrhage with subsequent ulcer formation at these sites.

Several studies have shown that in advanced chronic venous insufficiency, elastic compression bandages reduce the peak venous systolic pressure achieved during walking, thereby modifying deleterious ambulatory venous hypertension.8,9 In addition, interstitial fluid collection producing edema is reduced by the action of elastic compression on interstitial fluid pressure with resultant reduction of capillary leakage.10

## Wound Dressings

Over the last quarter century there has been a major shift in the type of dressing used for wounds. Earlier it was common practice to leave a wound as dry as possible so that the dressing principally served to keep infections out and reduce trauma to the wound. The pioneering experiments of Winter and Associates10 showed in a porcine wound model a markedly increased healing rate when an occlusive dressing was used. This experimental finding was subsequently validated in a clinical study.12 Limbs with occlusive dressings that promote a moist wound-healing environment had a 40% increased epithelialization rate over dry bandaged wounds. Based on these findings the type of dressings slowly shifted in the 1970’s and 1980’s to semi-occlusive and occlusive dressings. This marked a major advance in wound therapy as stated by Falanga: “The composition and properties of a dressing itself now play a major role in modifying the wound micro-environment.”13 In addition to wound dressings, which promote a warm moist wound environment by reducing water evaporation and heat loss as well as preventing crust formation, a new approach involving biologic dressings is being developed. This class of dressings stimulates important growth factors that are necessary in promoting wound healing.

Winter has classified wound dressings as to their degree of activity with the wound: passive, interactive and active dressings.11 Dressing types have been further divided into four classes: 1) nonocclusive, 2) semi-occlusive, 3) occlusive, and 4) biologic. The first three types are based on the degree that the wound dressing reduces water vapor and heat loss from the wound. By contrast, the fourth type, biological dressings, comprise those dressings which either provide directly a growth factor that accelerates wound healing or a factor that indirectly stimulates important growth substances.

One working principle is that no wound dressing may be ideal for all wounds, and the type of dressings may change as wound healing and other local wound factors progress. Nonocclusive dressing, such as topical antibiotics covered with dry gauze, simply protects the wound from trauma and potential infection and is classified as a passive dressing. By contrast, the interactive types of wound dressings (semi-occlusive and occlusive dressings) maintain a moist wound environment and may help to control the amount and composition of wound exudate. The most common example of a semi-occlusive dressing is the saline wet to dry gauze dressing. This dressing may facilitate moist healing if the gauze is kept wet, but when the gauze is dried out the dressing is non-occlusive and serves to debride the wound. Unfortunately, the dry gauze also may remove cells important in wound healing. The wet gauze also has the potential for macerating the peri-wound skin.

## Common Types of Semi-Occlusive and Occlusive Dressing: Dressing Properties and Mechanism of Action

Reviewed in this section are different types of dressings and their mechanism of action.14 Film dressings are composed of transparent and adherent polyurethane that transmit water vapor, oxygen, and carbon dioxide from the wound. These dressings both protect and insulate the wound as well as providing autolytic debridement of the eschar. Unfortunately, film dressings do not absorb drainage and maceration of the surrounding skin can occur. Examples of this are Opsite^®^, and Tegaderm^®^.

Hydrocolloid dressings are composed of a water-impermeable outer layer, containing pure polyurethane and an inner hydrocolloid layer. These dressings have the properties of debridement and protection---similar to the film dressings---but allow some absorption of wound drainage. They are probably less permeable than film dressings. Examples of this type are Duo Derm^®^, Comfeel^®^, and SignaDress^®^.

Hydrogel dressings are semi-transparent non-adherent hydrogels that are generally provided in sheets. These dressings are composed of insoluble polymers with hydrophilic substitutes that absorb water like Tegagel^®^.

Foam dressings absorb significant quantities of exudate from the wound and are comprised of siolastic or polyurethane foam. These dressings are permeable to gases and water vapor while the hydrophobic properties of the back of the dressings mitigate penetration of liquid. An example of this type is Allevyn^®^.

Alginate dressings are composed of sodium alginate, which is extracted from brown seaweed. This type of dressing has excellent absorptive capabilities and can be used in infected wounds as exemplified by Sorbsan^®^.

Biologic dressings, the fourth type of wound dressings, can be subdivided into: 1) living human dermal equivalent (artificial skin), 2) platelet products (either autologous or recombinant DNA technology), and 3) other growth factors. There are currently two types of living human dermal equivalent. The first type contains kerotinocytes (cells occupying the outer layer of the skin or epidermis) as well as fibroblasts (the dermis) on a collagen matrix (Apligraf^®^). Both types of cells (keratinocytes and fibroblasts) are derived from cultured neonatal foreskins. Dermagraft^®^, the second type of living human dermal equivalent, contains no epithelial layer (kerotinocytes) but is constructed of dermis (fibroblasts) alone on a collagen matrix. While these skin equivalents provide temporary coverage of the wound, their main mode of action is through secreting and stimulating wound growth factors. Endogenous cells migrate into the wound to promote healing. Clinical studies with Apligraf^®^ have shown an approximately 40% “take” of the fetal derived kerotinocytes.

The most commonly used topical biologic “growth factor” is a platelet derived growth factor, Regranax^®^ (becaplermin), which is produced by recombinant DNA technology. The gel is applied topically to the wound and promotes chemotactic recruitment and proliferation of cells as well as increasing angiogenesis. Other growth factors such as autologous platelet-thrombin, epidermal growth factor, fibroblast growth factor, and granulocyte macrophage colony stimulation factor, have been explored recently in small trials.