# Evidence Table per FDA Draft Guidance Document Venous ulcers

Evidence Table - RCTS of venous ulcers (additional data on 20 selected studies)