# Evidence Table per FDA Draft Guidance Document Pressure Ulcers

Evidence Table - RCTS of pressure ulcers (additional data on 20 selected studies)