# Evidence Table per FDA Draft Guidance Document Diabetic ulcers

Evidence Table - RCTs of diabetic ulcers (additional data on 20 selected studies)