# Evidence Table – Mixed Ulcers

Background Care in RCTs of Mixed or Non-descriptive Chronic Ulcers