# Evidence Table – Arterial Ulcers

Background Care in RCT of Arterial Ulcers