# Evidence Table – Venous Ulcers

Background Care in RCTS of Venous Ulcers