# Evidence Table – Pressure Ulcers

Background Care in RCTS of Pressure Ulcers