# Evidence Table – Diabetic Ulcers

Background Care in RCTS of Diabetic Ulcers