# List of Randomized Controlled Trials Examined in This Report

## Reference List

1 Abidia A, Laden G, Kuhan G, Johnson BF, Wilkinson AR, Renwick PM, et al. The role of hyperbaric oxygen therapy in ischaemic diabetic lower extremity ulcers: a double-blind randomised-controlled trial.[see comment]. European Journal of Vascular & Endovascular Surgery. 2003;25(6):513-518. [pmid: 12787692].
2 Adegoke BO, Badmos KA. Acceleration of pressure ulcer healing in spinal cord injured patients using interrupted direct current. African Journal of Medicine & Medical Sciences. 2001;30(3):195-197. [pmid: 14510128].
3 Agrawal RP, Agrawal S, Beniwal S, Joshi CP, Kochar DK. Granulocyte-macrophage colony-stimulating factor in foot ulcers. Diabetic Foot. 2003;6(2):93-97. 2003 Summer.(22 ref).
4 Ahroni JH. The care of lower extremity lesions in patients with diabetes. Nurse Practitioner Forum. 1991;2(3):188-192. [pmid: 1840973].
5 Alvarez OM FA. Chemical debridement of pressure ulcers: a prospective, randomized, comparative trial of collagenase and papain/urea formulations. Wounds-A Compendium of Clinical Research & Practice. 2000;12(2):15-25.
6 Alvarez OM, FernandezObregon A, Rogers RS, Bergamo L, Masso J, Black M. A prospective, randomized, comparative study of collagenase and papain-urea for pressure ulcer debridement. Wounds-A Compendium of Clinical Research & Practice. 2003;15(4):293-301. 2003 Apr.(32 ref).
7 Alvarez OM, Rogers RS, Booker JG, Patel M. Effect of noncontact normothermic wound therapy on the healing of neuropathic (diabetic) foot ulcers: an interim analysis of 20 patients. Journal of Foot & Ankle Surgery. 2003;42(1):30-35. [pmid: 12567365].
8 Andersen KE FCG. A randomized, controlled study to compare the effectiveness of two foam dressings in the management of lower leg ulcers. Ostomy Wound Management. 2002;48(8):34-41.
9 Armstrong DG, Nguyen HC. Improvement in healing with aggressive edema reduction after debridement of foot infection in persons with diabetes.[see comment]. Archives of Surgery. 2000;135(12):1405-1409. [pmid: 11115342].
10 Armstrong SH, Ruckley CV. Use of a fibrous dressing in exuding leg ulcers. Journal of Wound Care. 1997;6(7):322-324. [pmid: 9325826].
11 Arosio E, Ferrari G, Santoro L, Gianese F, Coccheri S. Mesoglycan Venous Insufficiency Group. A placebo-controlled, double-blind study of mesoglycan in the treatment of chronic venous ulcers. European Journal of Vascular & Endovascular Surgery. 2001;22(4):365-372. [pmid: 11563899].
12 Atillasoy E. The safety and efficacy of Graftskin (APLIGRAF) in the treatment of venous leg ulcers: a multicenter, randomized, controlled clinical trial. Wounds-A Compendium of Clinical Research & Practice. Suppl A. 2000;12(5):20A-26A. 2000 Sep-Oct.(18 ref).
13 Baker LL CR. Effects of electrical stimulation on wound healing in patients with diabetic ulcers. Diabetes Care. 1997;20(3):405-412. [pmid: 9051395].
14 Bale S, Squires D, Varnon T, Walker A, Benbow M, Harding KG. A comparison of two dressings in pressure sore management. Journal of Wound Care. 1997;6(10):463-466. [pmid: 9455271].
15 Bale S, Banks V, Haglestein S, Harding KG. A comparison of two amorphous hydrogels in the debridement of pressure sores. Journal of Wound Care. 1998;7(2):65-68. [pmid: 9543975].
16 Barwell JR, Davies CE, Deacon J, Harvey K, Minor J, Sassano A, et al. Comparison of surgery and compression with compression alone in chronic venous ulceration (ESCHAR study): randomised controlled trial. Lancet. 2004;363(9424):1854-1859. [pmid: 15183623].
17 Belcaro G, Cesarone MR, Nicolaides AN, De Sanctis MT, Incandela L, Geroulakos G. Treatment of venous ulcers with pentoxifylline: a 6-month randomized, double-blind, placebo controlled trial. Angiology. 2002;53. Suppl-7.
18 Belcaro G, Cesarone MR, Nicolaides AN, Geroulakos G, Di Renzo A, Milani M, et al. Improvement of microcirculation and healing of venous hypertension and ulcers with Crystacide. Evaluation of free radicals, laser Doppler flux and PO2. A prospective-randomized-controlled study. Angiology. 2003;54(3):325-330. [pmid: 12785025].
19 Belmin J, Meaume S, Rabus MT, Bohbot S. Investigators of the Sequential Treatment of the Elderly with Pressure Sores (STEPS) Trial. Sequential treatment with calcium alginate dressings and hydrocolloid dressings accelerates pressure ulcer healing in older subjects: a multicenter randomized trial of sequential versus nonsequential treatment with hydrocolloid dressings alone. Journal of the American Geriatrics Society. 2002;50(2):269-274. [pmid: 12028208].
20 Burgos A. Cost, efficacy, efficiency and tolerability of collagenase ointment versus hydrocolloid occlusive dressing in the treatment of pressure ulcers. A comparative, randomised, multicentre study. Clinical Drug Investigation. 2000;19(5):357-365.
21 Burgos A. Collagenase ointment application at 24- versus 48-hour intervals in the treatment of pressure ulcers. A randomised multicentre study. Clinical Drug Investigation. 2000;19(6):399-407.
22 Burke DT, Ho CH, Saucier MA, Stewart G. Effects of hydrotherapy on pressure ulcer healing. American Journal of Physical Medicine & Rehabilitation. 1998;77(5):394-398. [pmid: 9798830].
23 Caravaggi C, Faglia E, De Giglio R, Mantero M, Quarantiello A, Sommariva E, et al. Effectiveness and safety of a nonremovable fiberglass off-bearing cast versus a therapeutic shoe in the treatment of neuropathic foot ulcers: a randomized study. Diabetes Care. 2000;23(12):1746-1751. [pmid: 11128345].
24 Caravaggi C, De Giglio R, Pritelli C, Sommaria M, Dalla NS, Faglia E, et al. HYAFF 11-based autologous dermal and epidermal grafts in the treatment of noninfected diabetic plantar and dorsal foot ulcers: a prospective, multicenter, controlled, randomized clinical trial. Diabetes Care. 2003;26(10):2853-2859. [pmid: 14514591].
25 Chang DW, Sanchez LA, Veith FJ, Wain RA, Okhi T, Suggs WD. Can a tissue-engineered skin graft improve healing of lower extremity foot wounds after revascularization?. Annals of Vascular Surgery. 2000;14(1):44-49. [pmid: 10629263].
26 Charles H. Randomised, comparative study of three primary dressings for the treatment of venous ulcers. British Journal of Community Nursing. 2002;7(6 Suppl):48-54. [pmid: 12066081].
27 Chin GA, Thigpin TG, Perrin KJ, Moldawer LL, Schultz GS. Biochemistry of wound healing. Treatment of chronic ulcers in diabetic patients with a topical metalloproteinase inhibitor, doxycycline. Wounds-A Compendium of Clinical Research & Practice. 2003;15(10):315-323. 2003 Oct.(38 ref).
28 Coccheri S, Scondotto G, Agnelli G, Aloisi D, Palazzini E, Zamboni V, et al. Randomised, double blind, multicentre, placebo controlled study of sulodexide in the treatment of venous leg ulcers. Thrombosis & Haemostasis. 2002;87(6):947-952. [pmid: 12083500].
29 d'Hemecourt PA SJKM. Sodium carboxymethyl cellulose aqueous-based gel vs becaplermin gel in patients with nonhealing lower extremity diabetic ulcers. Wounds-A Compendium of Clinical Research & Practice. 1998;10(3):69-75.
30 Da Costa RM, Ribeiro Jesus FM, Aniceto C, Mendes M. Randomized, double-blind, placebo-controlled, dose-ranging study of granulocyte-macrophage colony stimulating factor in patients with chronic venous leg ulcers. Wound Repair & Regeneration. 1999;7(1):17-25. [pmid: 10231502].
31 Dale JJ, Ruckley CV, Harper DR, Gibson B, Nelson EA, Prescott RJ. Randomised, double blind placebo controlled trial of pentoxifylline in the treatment of venous leg ulcers.[see comment][erratum appears in BMJ 2000 Jan 1;320 (7226):30]. BMJ. 1999;319(7214):875-878. [pmid: 10506039].
32 Danielsen L, Madsen M, Henriksen L, Sindrup J, Petersen L. Subbandage pressure measurements comparing a long-stretch with a short-stretch compression bandage. Acta Dermato-Venereologica. 1998;78(3):201-204. [pmid: 9602227].
33 Danielsen L. Venous leg ulcer healing: a randomized prospective study of long-stretch versus short-stretch compression bandages. Phlebology. 1998;Vol. 13:59-63. 1998.:-63.
34 de Lalla F, Pellizzer G, Strazzabosco M, Martini Z, Du JG, Lora L, et al. Randomized prospective controlled trial of recombinant granulocyte colony-stimulating factor as adjunctive therapy for limb-threatening diabetic foot infection. Antimicrobial Agents & Chemotherapy. 2001;45(4):1094-1098. [pmid: 11257020].
35 De Sanctis MT, Belcaro G, Cesarone MR, Ippolito E, Nicolaides AN, Incandela L, et al. Treatment of venous ulcers with pentoxifylline: a 12-month, double-blind, placebo controlled trial. Microcirculation and healing. Angiology. 2002;53. Suppl-51.
36 Dehlin O, Elmstahl S, Gottrup F. Monochromatic phototherapy in elderly patients: a new way of treating chronic pressure ulcers?. Aging-Clinical & Experimental Research. 2003;15(3):259-263. [pmid: 14582689].
37 DePalma RG KD. Comparison of costs and healing rates of two forms of compression in treating venous ulcers. Vascular Surgery. 1999;33(6):683-690.
38 Dmochowska M, Prokop J, Bielecka S, Urasinska K, Krolicki A, Nagaj E, et al. A randomized, controlled, parallel group clinical trial of a polyurethane foam dressing versus a calcium alginate dressing in the treatment of moderately to heavily exuding venous leg ulcers. Wounds-A Compendium of Clinical Research & Practice. 1999;11(1):21-28. 1999 Jan-Feb.(20 ref).
39 Donaghue VM, Chrzan JS, Rosenblum BI, Giurini JM, Habershaw GM, Veves A. Evaluation of a collagen-alginate wound dressing in the management of diabetic foot ulcers. Advances in Wound Care. 1998;11(3):114-119. [pmid: 9729942].
40 Eginton MT, Brown KR, Seabrook GR, Towne JB, Cambria RA. A prospective randomized evaluation of negative-pressure wound dressings for diabetic foot wounds. Annals of Vascular Surgery. 2003;17(6):645-649. [pmid: 14534844].
41 Falabella AF, Carson P, Eaglstein WH, Falanga V. The safety and efficacy of a proteolytic ointment in the treatment of chronic ulcers of the lower extremity. Journal of the American Academy of Dermatology. 1998;39((5:Pt 1)). t-40.
42 Falanga V, Margolis D, Alvarez O, Auletta M, Maggiacomo F, Altman M, et al. Rapid healing of venous ulcers and lack of clinical rejection with an allogeneic cultured human skin equivalent. Human Skin Equivalent Investigators Group.[see comment]. Archives of Dermatology. 1998;134(3):293-300. [pmid: 9521027].
43 Falanga V, Sabolinski M. A bilayered living skin construct (APLIGRAF) accelerates complete closure of hard-to-heal venous ulcers. Wound Repair & Regeneration. 1999;7(4):201-207. [pmid: 10781211].
44 Falanga V, Fujitani RM, Diaz C, Hunter G, Jorizzo J, Lawrence PF, et al. Systemic treatment of venous leg ulcers with high doses of pentoxifylline: efficacy in a randomized, placebo-controlled trial. Wound Repair & Regeneration. 1999;7(4):208-213. [pmid: 10781212].
45 Falanga VJ. Tissue engineering in wound repair. Advances in Skin & Wound Care. 2000;13(2:Suppl). Suppl-9.
46 Ford CN REY. Interim analysis of a prospective, randomized trial of vacuum-assisted closure versus the healthpoint system in the management of pressure ulcers. Annals of Plastic Surgery. 2002;49(1):55-61. [pmid: 12142596].
47 Franek A, Polak A, Kucharzewski M. Modern application of high voltage stimulation for enhanced healing of venous crural ulceration. Medical Engineering & Physics. 2000;22(9):647-655. [pmid: 11259933].
48 Franek A, Krol P, Kucharzewski M. Does low output laser stimulation enhance the healing of crural ulceration? Some critical remarks. Medical Engineering & Physics. 2002;24(9):607-615. [pmid: 12376047].
49 Franks PJ MCEDC. Quality of life in venous ulceration: A randomized trial of two bandage systems. Phlebology. 1999;14(3):95-99.
50 Fumal I, Braham C, Paquet P, PierardFranchimont C, Pierard GE. The beneficial toxicity paradox of antimicrobials in leg ulcer healing impaired by a polymicrobial flora: a proof-of-concept study. Dermatology. 2002;204. Suppl-4.
51 Gherardini G, Gurlek A, Evans GR, Milner SM, Matarasso A, Wassler M, et al. Venous ulcers: improved healing by iontophoretic administration of calcitonin gene-related peptide and vasoactive intestinal polypeptide. Plastic & Reconstructive Surgery. 1998;101(1):90-93. [pmid: 9427920].
52 Gough A, Clapperton M, Rolando N, Foster AV, PhilpottHoward J, Edmonds ME. Randomised placebo-controlled trial of granulocyte-colony stimulating factor in diabetic foot infection.[see comment]. Lancet. 1997;350(9081):855-859. [pmid: 9310604].
53 Gould DJ, Campbell S, Newton H, Duffelen P, Griffin M, Harding EF. Setopress vs Elastocrepe in chronic venous ulceration. British Journal of Nursing. 1998;7(2):66-70. [pmid: 9510680].
54 Graumlich JF, Blough LS, McLaughlin RG, Milbrandt JC, Calderon CL, Agha SA, et al. Healing pressure ulcers with collagen or hydrocolloid: a randomized, controlled trial. Journal of the American Geriatrics Society. 2003;51(2):147-154. [pmid: 12558709].
55 Guilhou JJ, Fevrier F, Debure C, Dubeaux D, GilletTerver MN, Guillot B, et al. Benefit of a 2-month treatment with a micronized, purified flavonoidic fraction on venous ulcer healing. A randomized, double-blind, controlled versus placebo trial. International Journal of Microcirculation: Clinical & Experimental. 1997;17. Suppl-6.
56 Gupta AK, Filonenko N, Salansky N, Sauder DN. The use of low energy photon therapy (LEPT) in venous leg ulcers: a double-blind, placebo-controlled study. Dermatologic Surgery. 1998;24(12):1383-1386. [pmid: 9865208].
57 Hanft JR, Surprenant MS. Healing of chronic foot ulcers in diabetic patients treated with a human fibroblast-derived dermis. Journal of Foot & Ankle Surgery. 2002;41(5):291-299. [pmid: 12400712].
58 Hansson C. The effects of cadexomer iodine paste in the treatment of venous leg ulcers compared with hydrocolloid dressing and paraffin gauze dressing. Cadexomer Iodine Study Group. International Journal of Dermatology. 1998;37(5):390-396. [pmid: 9620490].
59 Harding KG, Price P, Robinson B, Thomas S, Hofman D. Cost and dressing evaluation of hydrofiber and alginate dressings in the management of community-based patients with chronic leg ulceration. Wounds-A Compendium of Clinical Research & Practice. 2001;13(6):229-236. 2001 Nov–3Dec.(16 ref).
60 Hirshberg J, Coleman J, Marchant B, Rees RS. TGF-beta3 in the treatment of pressure ulcers: a preliminary report. Advances in Skin & Wound Care. 2001;14(2):91-95. [pmid: 11899912].
61 Houghton PE, Kincaid CB, Lovell M, Campbell KE, Keast DH, Woodbury MG, et al. Effect of electrical stimulation on chronic leg ulcer size and appearance. Physical Therapy. 2003;83(1):17-28. [pmid: 12495409].
62 Jensen JL, Seeley J, Gillin B. Diabetic foot ulcerations. A controlled, randomized comparison of two moist wound healing protocols: Carrasyn Hydrogel Wound dressing and wet-to-moist saline gauze. Advances in Wound Care. 1998;11(7:Suppl). Suppl-4.
63 Joseph E, Hamori CA, Bergman S, Roaf E, Swann NF, Anastasi GW. New therapeutic approaches in wound care. A prospective randomized trial of vacuum-assisted closure versus standard therapy of chronic nonhealing wounds. Wounds-A Compendium of Clinical Research & Practice. 2000;12(3):60-67. 2000 May-Jun.(13 ref).
64 Kalani M, Apelqvist J, Blomback M, Brismar K, Eliasson B, Eriksson JW, et al. Effect of dalteparin on healing of chronic foot ulcers in diabetic patients with peripheral arterial occlusive disease: a prospective, randomized, double-blind, placebo-controlled study.[see comment]. Diabetes Care. 2003;26(9):2575-2580. [pmid: 12941721].
65 Kallianinen LK, Hirshberg J, Marchant B, Rees RS. Role of platelet-derived growth factor as an adjunct to surgery in the management of pressure ulcers. Plastic & Reconstructive Surgery. 2000;106(6):1243-1248. [pmid: 11083552].
66 Kastenbauer T, Hornlein B, Sokol G, Irsigler K. Evaluation of granulocyte-colony stimulating factor (Filgrastim) in infected diabetic foot ulcers. Diabetologia. 2003;46(1):27-30. [pmid: 12637979].
67 Kessler L, Bilbault P, Ortega F, Grasso C, Passemard R, Stephan D, et al. Hyperbaric oxygenation accelerates the healing rate of nonischemic chronic diabetic foot ulcers: a prospective randomized study. Diabetes Care. 2003;26(8):2378-2382. [pmid: 12882865].
68 Kloth LC, Berman JE, Nett M, Papanek PE, DumitMinkel S. A randomized controlled clinical trial to evaluate the effects of noncontact normothermic wound therapy on chronic full-thickness pressure ulcers. Advances in Skin & Wound Care. 2002;15(6):270-276. [pmid: 12477979].
69 Koblik T, Sieradzki J, Sendur R, Biernat J, Czarnobilski K, Gryz E, et al. The effect of insulin and sulodexide (Vessel Due F) on diabetic foot syndrome: pilot study in elderly patients. Journal of Diabetes & its Complications. 2001;15(2):69-74. [pmid: 11274902].
70 Koksal C, Bozkurt AK. Combination of hydrocolloid dressing and medical compression stockings versus Unna's boot for the treatment of venous leg ulcers. Swiss Medical Weekly. 2003;133(25–26):364-368. [pmid: 12947533].
71 Kumar S, Samraj K, Nirujogi V, Budnik J, Walker MA. Intermittent pneumatic compression as an adjuvant therapy in venous ulcer disease. Journal of Tissue Viability. 2002;12(2):42-44. [pmid: 12001325].
72 Lagan KM, McKenna T, Witherow A, Johns J, McDonough SM, Baxter GD. Low-intensity laser therapy/combined phototherapy in the management of chronic venous ulceration: a placebo-controlled study. Journal of Clinical Laser Medicine & Surgery. 2002;20(3):109-116. [pmid: 12165122].
73 Lalau JD, Bresson R, Charpentier P, Coliche V, Erlher S, Ha VG, et al. Efficacy and tolerance of calcium alginate versus vaseline gauze dressings in the treatment of diabetic foot lesions. Diabetes & Metabolism. 2002;28(3):223-229. [pmid: 12149603].
74 Limova M. Controlled, randomized clinical trial of 2 hydrocolloid dressings in the management of venous insufficiency ulcers. Journal of Vascular Nursing. 2002;20(1):22-32. [pmid: 11938346].
75 Limova M. Evaluation of two calcium alginate dressings in the management of venous ulcers. Ostomy Wound Management. 2003;49(9):26-33.
76 Lindgren C, Marcusson JA, Toftgard R. Treatment of venous leg ulcers with cryopreserved cultured allogeneic keratinocytes: a prospective open controlled study. British Journal of Dermatology. 1998;139(2):271-275. [pmid: 9767241].
77 Lipkin S, Chaikof E, Isseroff Z, Silverstein P. Effectiveness of bilayered cellular matrix in healing of neuropathic diabetic foot ulcers: results of a multicenter pilot trial. Wounds-A Compendium of Clinical Research & Practice. 2003;15(7):230-236. 2003 Jul.(21 ref).
78 Ljungberg S. Comparison of dextranomer paste and saline dressings for management of decubital ulcers. Clinical Therapeutics. 1998;20(4):737-743. [pmid: 9737833].
79 Ljungberg S. Dextranomer for treatment of venous leg ulcers: Paste versus bead formulation. Current Therapeutic Research, Clinical & Experimental. 1998;Vol. 59(7):498-502.
80 Lucas C. The effect of low level laser therapy (LLLT) on stage III decubitus ulcers (pressure sores); A prospective randomised single blind, multicentre pilot study. Lasers in Medical Science. 2000;15(2):94-100.
81 Lyon RT, Veith FJ, Bolton L, Machado F. Clinical benchmark for healing of chronic venous ulcers. Venous Ulcer Study Collaborators. American Journal of Surgery. 1998;176(2):172-175. [pmid: 9737626].
82 Marques dC. Double-blind randomized placebo-controlled trial of the use of granulocyte-macrophage colony-stimulating factor in chronic leg ulcers. American Journal of Surgery. 1997;173(3):165-168. [pmid: 9124619].
83 Marston WA, Hanft J, Norwood P, Pollak R. Dermagraft Diabetic Foot Ulcer Study Group. The efficacy and safety of Dermagraft in improving the healing of chronic diabetic foot ulcers: results of a prospective randomized trial. Diabetes Care. 2003;26(6):1701-1705. [pmid: 12766097].
84 Martinezde Jesus FR MM. Randomized single-blind trial of topical ketanserin for healing acceleration of diabetic foot ulcers. Archives of Medical Research. 1997;28(1):95-99. [pmid: 9078595].
85 Matzen S, Peschardt A, Alsbjorn B. A new amorphous hydrocolloid for the treatment of pressure sores: a randomised controlled study. Scandinavian Journal of Plastic & Reconstructive Surgery & Hand Surgery. 1999;33(1):13-15. [pmid: 10207960].
86 McCallon SK, Knight CA, Valiulus JP, Cunningham MW, McCulloch JM, Farinas LP. Vacuum-assisted closure versus saline-moistened gauze in the healing of postoperative diabetic foot wounds. Ostomy Wound Management. 2000;46(8):28-32.
87 McCulloch J, Knight CA. Noncontact normothermic wound therapy and offloading in the treatment of neuropathic foot ulcers in patients with diabetes. Ostomy Wound Management. 2002;48(3):38-44.
88 Meyer FJ, Burnand KG, Lagattolla NR, Eastham D. Randomized clinical trial comparing the efficacy of two bandaging regimens in the treatment of venous leg ulcers.[see comment]. British Journal of Surgery. 2002;89(1):40-44. [pmid: 11851661].
89 Meyer FJ, McGuinness CL, Lagattolla NR, Eastham D, Burnand KG. Randomized clinical trial of three-layer paste and four-layer bandages for venous leg ulcers.[see comment]. British Journal of Surgery. 2003;90(8):934-940. [pmid: 12905544].
90 Milstone L, Asgari MM, Schwartz PM, Hardin-Young J. Growth factor expression, healing, and structural characteristics of graftskin (apligraf). Wounds-A Compendium of Clinical Research & Practice. 2000;12(5(Supp A)):12A-19A.
91 Moffatt CJ SDFPC. Randomised trial comparing two four-layer bandage systems in the management of chronic leg ulceration. Phlebology. 1999;14(4):139-142.
92 Moffatt CJ, McCullagh L, O'Connor T, Doherty DC, Hourican C, Stevens J, et al. Randomized trial of four-layer and two-layer bandage systems in the management of chronic venous ulceration. Wound Repair & Regeneration. 2003;11(3):166-171. [pmid: 12753596].
93 Moody M. Clinical. Comparison of Rosidal K and SurePress in the treatment of venous leg ulcers. British Journal of Nursing. 1999;8(6):345-346. 348, 350 passim, 1999 Mar 25-Apr 7.(8 ref). [pmid: 10409957].
94 Motta G, Dunham L, Dye T, Mentz J, O'ConnellGifford E, Smith E. Clinical efficacy and cost-effectiveness of a new synthetic polymer sheet wound dressing. Ostomy Wound Management. 1999;45(10):41-46.
95 Mueller MJ, Sinacore DR, Hastings MK, Strube MJ, Johnson JE. Effect of Achilles tendon lengthening on neuropathic plantar ulcers. A randomized clinical trial.[see comment]. Journal of Bone & Joint Surgery - American Volume. 2003;85-A(8):1436-1445.
96 Navratilova Z, Slonkova V, Semradova V, Adler J. Cryopreserved and lyophilized cultured epidermal allografts in the treatment of leg ulcers: a pilot study. Journal of the European Academy of Dermatology & Venereology. 2004;18(2):173-179. [pmid: 15009297].
97 Neander KD, Hesse F. The protective effects of a new preparation on wound edges. Journal of Wound Care. 2003;12(10):369-371. [pmid: 14648962].
98 Nikolovska S, Pavlova L, Petrova N, Gocev G, Ivanovski M. Pentoxifylline--efficient in the treatment of venous ulcers in the absence of compression?. Acta Dermatovenerologica Croatica. 2002;10(1):9-13. [pmid: 12137725].
99 O'Brien JF, Grace PA, Perry IJ, Hannigan A, Clarke MM, Burke PE. Randomized clinical trial and economic analysis of four-layer compression bandaging for venous ulcers.[see comment]. British Journal of Surgery. 2003;90(7):794-798. [pmid: 12854102].
100 Omar AA, Mavor AI, Jones AM, HomerVanniasinkam S. Treatment of venous leg ulcers with Dermagraft. European Journal of Vascular & Endovascular Surgery. 2004;27(6):666-672. [pmid: 15121121].
101 Pai MR, Sitaraman N, Kotian MS. Topical phenytoin in diabetic ulcers: a double blind controlled trial. Indian Journal of Medical Sciences. 2001;55(11):593-599. [pmid: 12508631].
102 Partsch H, Damstra RJ, Tazelaar DJ, SchullerPetrovic S, Velders AJ, de Rooij MJ, et al. Multicentre, randomised controlled trial of four-layer bandaging versus short-stretch bandaging in the treatment of venous leg ulcers. Vasa. 2001;30(2):108-113. [pmid: 11417280].
103 Peschen M. Low-frequency ultrasound treatment of chronic venous leg ulcers in an outpatient therapy. Acta Dermato-Venereologica. 1997;77(4):311-314. [pmid: 9228227].
104 Pham HT RBLTGJCJHGV. Evaluation of a human skin equivalent for the treatment of diabetic foot ulcers in a prospective, randomized, clinical trial. Wounds-A Compendium of Clinical Research & Practice. 1999;11(4):79-86.
105 Piaggesi A, Schipani E, Campi F, Romanelli M, Baccetti F, Arvia C, et al. Conservative surgical approach versus non-surgical management for diabetic neuropathic foot ulcers: a randomized trial. Diabetic Medicine. 1998;15(5):412-417. [pmid: 9609364].
106 Piaggesi A, Baccetti F, Rizzo L, Romanelli M, Navalesi R, Benzi L. Sodium carboxyl-methyl-cellulose dressings in the management of deep ulcerations of diabetic foot. Diabetic Medicine. 2001;18(4):320-324. [pmid: 11437864].
107 Pollak RA, Edington H, Jensen JL, Kroeker RO, Gentzkow GD. A human dermal replacement for the treatment of diabetic foot ulcers. Wounds-A Compendium of Clinical Research & Practice. 1997;9(6):175-183. 1997 Nov-Dec.(21 ref).
108 Prescott RJ NEDJHDRC. Design of randomized controlled trials in the treatment of leg ulcers: More answers with fewer patients. Phlebology. 1998;13(3):107-112.
109 Price P, Bale S, Crook H, Harding KG. The effect of a radiant heat dressing on pressure ulcers. Journal of Wound Care. 2000;9(4):201-205. [pmid: 11933306].
110 Pullen R, Popp R, Volkers P, Fusgen I. Prospective randomized double-blind study of the wound-debriding effects of collagenase and fibrinolysin/deoxyribonuclease in pressure ulcers. Age & Ageing. 2002;31(2):126-130. [pmid: 11937475].
111 Puttirutvong P. Meshed skin graft versus split thickness skin graft in diabetic ulcer coverage. Journal of the Medical Association of Thailand. 2004;87(1):66-72. [pmid: 14971537].
112 Razzak FA AMKSAAA. Local insulin therapy in diabetic foot. Jk Practitioner. 1997;4(1):6-8.
113 Rhodes RS, Heyneman CA, Culbertson VL, Wilson SE, Phatak HM. Topical phenytoin treatment of stage II decubitus ulcers in the elderly. Annals of Pharmacotherapy. 2001;35(6):675-681. [pmid: 11408983].
114 Rice B, Kalker AJ, Schindler JV, Dixon RM. Effect of biofeedback-assisted relaxation training on foot ulcer healing. Journal of the American Podiatric Medical Association. 2001;91(3):132-141. [pmid: 11266495].
115 Robinson C. Warm-Up Active Wound Therapy: a novel approach to the management of chronic venous stasis ulcers. Journal of Vascular Nursing. 1998;16(2):38-42. [pmid: 9735735].
116 Robson MC, Hill DP, Smith PD, Wang X, MeyerSiegler K, Ko F, et al. Sequential cytokine therapy for pressure ulcers: clinical and mechanistic response. Annals of Surgery. 2000;231(4):600-611. [pmid: 10749622].
117 Robson MC, Phillips TJ, Falanga V, Odenheimer DJ, Parish LC, Jensen JL, et al. Randomized trial of topically applied repifermin (recombinant human keratinocyte growth factor-2) to accelerate wound healing in venous ulcers. Wound Repair & Regeneration. 2001;9(5):347-352. [pmid: 11896977].
118 Robson MC, Steed DL, McPherson JM, Pratt BM. Effects of transforming growth factor s2 on wound healing in diabetic foot ulcers: a randomized controlled safety and dose-ranging trial. Journal of Applied Research. 2002;2(2):133-145. 2002 Summer.(24 ref).
119 Romanelli M. Objective measurement of venous ulcer debridement and granulation with a skin color reflectance analyzer. Wounds-A Compendium of Clinical Research & Practice. 1997;9(4):122-126. 1997 Jul-Aug.(11 ref).
120 Rosenthal MJ, Felton RM, Nastasi AE, Naliboff BD, Harker J, Navach JH. Healing of advanced pressure ulcers by a generic total contact seat: 2 randomized comparisons with low air loss bed treatments. Archives of Physical Medicine & Rehabilitation. 2003;84(12):1733-1742. [pmid: 14669176].
121 Roztocil K, Stvrtinova V, Strejcek J. Efficacy of a 6-month treatment with Daflon 500 mg in patients with venous leg ulcers associated with chronic venous insufficiency. International Angiology. 2003;22(1):24-31. [pmid: 12771852].
122 Saap LJ, Falanga V. Debridement performance index and its correlation with complete closure of diabetic foot ulcers. Wound Repair & Regeneration. 2002;10(6):354-359. [pmid: 12453138].
123 Sams HH, Chen J, King LE. Graftskin treatment of difficult to heal diabetic foot ulcers: one center's experience. Dermatologic Surgery. 2002;28(8):698-703. [pmid: 12174061].
124 Schulze HJ, Lane C, Charles H, Ballard K, Hampton S, Moll I. Evaluating a superabsorbent hydropolymer dressing for exuding venous leg ulcers. Journal of Wound Care. 2001;10(1):511-518. [pmid: 12964233].
125 Scondotto G, Aloisi D, Ferrari P, Martini L. Treatment of venous leg ulcers with sulodexide. Angiology. 1999;50(11):883-889. [pmid: 10580352].
126 Scriven JM, Taylor LE, Wood AJ, Bell PR, Naylor AR, London NJ. A prospective randomised trial of four-layer versus short stretch compression bandages for the treatment of venous leg ulcers. Annals of the Royal College of Surgeons of England. 1998;80(3):215-220. [pmid: 9682649].
127 Seaborne D, QuirionDeGirardi C, Rousseau M, Rivest M, Lambert J. The treatment of pressure sores using pulsed electromagnetic energy (PEME). Physiotherapy Canada. 1996;48(2):131-137. 96 A.D.; 1996 Spring.(35 ref).
128 Seeley J, Jensen JL, Hutcherson J. A randomized clinical study comparing a hydrocellular dressing to a hydrocolloid dressing in the management of pressure ulcers. Ostomy Wound Management. 1999;45(6):39-44.
129 Smiell JM, Wieman TJ, Steed DL, Perry BH, Sampson AR, Schwab BH. Efficacy and safety of becaplermin (recombinant human platelet-derived growth factor-BB) in patients with nonhealing, lower extremity diabetic ulcers: a combined analysis of four randomized studies. Wound Repair & Regeneration. 1999;7(5):335-346. [pmid: 10564562].
130 Sopata M, Luczak J, Ciupinska M. Effect of bacteriological status on pressure ulcer healing in patients with advanced cancer. Journal of Wound Care. 2002;11(3):107-110. [pmid: 11933727].
131 Stacey MC JAR. The influence of dressings on venous ulcer healing--a randomised trial. European Journal of Vascular & Endovascular Surgery. 1997;13(2):174-179. [pmid: 9091151].
132 Stacey MC, Mata SD, Trengove NJ, Mather CA. Randomised double-blind placebo controlled trial of topical autologous platelet lysate in venous ulcer healing. European Journal of Vascular & Endovascular Surgery. 2000;20(3):296-301. [pmid: 10986030].
133 Szor JK, Holewinski P. Lessons learned in research: an attempt to study the effects of magnetic therapy. Ostomy Wound Management. 2002;48(2):24-29. 2002 Feb.(13 ref).
134 Tankova T. Zinc hyaluronate in the treatment of diabetic foot ulcers: A controlled randomized open-label study. Diabetologia Croatica. 2002;30(3):93-96.
135 Tausche AK, Skaria M, Bohlen L, Liebold K, Hafner J, Friedlein H, et al. An autologous epidermal equivalent tissue-engineered from follicular outer root sheath keratinocytes is as effective as split-thickness skin autograft in recalcitrant vascular leg ulcers. Wound Repair & Regeneration. 2003;11(4):248-252. [pmid: 12846911].
136 Taylor AD TRMR. Prospective comparison of healing rates and therapy costs for conventional and four-layer high-compression bandaging treatments of venous leg ulcers. Phlebology. 1998;13(1):20-24.
137 Thomas DR, Goode PS, LaMaster K, Tennyson T. Acemannan hydrogel dressing versus saline dressing for pressure ulcers. A randomized, controlled trial. Advances in Wound Care. 1998;11(6):273-276. [pmid: 10326343].
138 Thomas S, Banks V, Bale S, FearPrice M, Hagelstein S, Harding KG, et al. A comparison of two dressings in the management of chronic wounds. Journal of Wound Care. 1997;6(8):383-386. [pmid: 9341430].
139 Thomas S, Banks V, Fear M, Hagelstein S, Bale S, Harding K. A study to compare two film dressings used as secondary dressings. Journal of Wound Care. 1997;6(7):333-336. [pmid: 9325828].
140 Tsang MW, Wong WK, Hung CS, Lai KM, Tang W, Cheung EY, et al. Human epidermal growth factor enhances healing of diabetic foot ulcers. Diabetes Care. 2003;26(6):1856-1861. [pmid: 12766123].
141 Ukat A, Konig M, Vanscheidt W, Munter KC. Short-stretch versus multilayer compression for venous leg ulcers: a comparison of healing rates. Journal of Wound Care. 2003;12(4):139-143. [pmid: 12715486].
142 Veves A, Falanga V, Armstrong DG, Sabolinski ML. Apligraf Diabetic Foot Ulcer Study. Graftskin, a human skin equivalent, is effective in the management of noninfected neuropathic diabetic foot ulcers: a prospective randomized multicenter clinical trial. Diabetes Care. 2001;24(2):290-295. [pmid: 11213881].
143 Veves A, Sheehan P, Pham HT. A randomized, controlled trial of Promogran (a collagen/oxidized regenerated cellulose dressing) vs standard treatment in the management of diabetic foot ulcers. Archives of Surgery. 2002;137(7):822-827. [pmid: 12093340].
144 Vin F, Teot L, Meaume S. The healing properties of Promogran in venous leg ulcers. Journal of Wound Care. 2002;11(9):335-341. [pmid: 12430368].
145 Wanner MB, Schwarzl F, Strub B, Zaech GA, Pierer G. Vacuum-assisted wound closure for cheaper and more comfortable healing of pressure sores: a prospective study. Scandinavian Journal of Plastic & Reconstructive Surgery & Hand Surgery. 2003;37(1):28-33. [pmid: 12625392].
146 Wayman J, Nirojogi V, Walker A, Sowinski A, Walker MA. The cost effectiveness of larval therapy in venous ulcers.[erratum appears in J Tissue Viability 2001 Jan;11(1):51]. Journal of Tissue Viability. 2000;10(3):91-94. [pmid: 11299572].
147 Whitney JD, Salvadalena G, Higa L, Mich M. Treatment of pressure ulcers with noncontact normothermic wound therapy: healing and warming effects. Journal of Wound, Ostomy, & Continence Nursing. 2001;28(5):244-252.
148 Wieman TJ, Smiell JM, Su Y. Efficacy and safety of a topical gel formulation of recombinant human platelet-derived growth factor-BB (becaplermin) in patients with chronic neuropathic diabetic ulcers. A phase III randomized placebo-controlled double-blind study. Diabetes Care. 1998;21(5):822-827. [pmid: 9589248].
149 Wieman TJ. Efficacy and safety of recombinant human platelet-derived growth factor-BB (becaplermin) in patients with chronic venous ulcers: a pilot study. Wounds-A Compendium of Clinical Research & Practice. 2003;15(8):257-264. 2003 Aug.
150 Wilkinson E, Buttfield S, Cooper S, Young E. Trial of two bandaging systems for chronic venous leg ulcers.[see comment][erratum appears in J Wound Care 1998 Jan;7(1):89]. Journal of Wound Care. 1997;6(7):339-340. [pmid: 9325829].
151 Zimny S, Meyer MF, Schatz H, Pfohl M. Applied felted foam for plantar pressure relief is an efficient therapy in neuropathic diabetic foot ulcers. Experimental & Clinical Endocrinology & Diabetes. 2002;110(7):325-328. [pmid: 12397530].
152 Zimny S, Schatz H, Pfohl U. The effects of applied felted foam on wound healing and healing times in the therapy of neuropathic diabetic foot ulcers. Diabetic Medicine. 2003;20(8):622-625. [pmid: 12873288].
153 Zur Nieden HC PR. Treatment of decubital ulcers in geriatric patients with ornithine- oxoglutarate - A randomized, double-blind pilot study. European Journal of Geriatrics. 1999;1(2):144-147.