# REFERENCES

References for the 148 RCTs examined in this report appear in appendix A. The actual number of citations listed is 153 because of duplicate and complementary publications.

1 Bradley M, Cullum N, Sheldon T. The debridement of chronic wounds: a systematic review. Health Tech Assess. 1999;Vol 3(No. 17 (Pt 1)).
2 Bradley M, Cullum N, Nelson EA, Petticrew M, Sheldon T, Torgerson D. Systematic reviews of wound care management: (2) Dressings and topical agents used in the healing of chronic wounds. Health Tech Assess. 1999;Vol 3(No. 17 (Pt 2)).
3 O’Meara, Cullum N, Majid M, Sheldon T. Systematic reviews of wound management: (3) antimicrobial agents for chronic wounds; (4) diabetic foot ulceration. Health Tech Assess. 2000;Vol 4(No. 21).
4 Cullum N, Nelson EA, Flemming K, Sheldon T. Systematic reviews of wound care management: (5) beds; (6) compression; (7) laser therapy, therapeutic ultrasound, electrotherapy and electromagnetic therapy. Health Tech Assess. 2001;Vol 5(No. 9).
5 Guidance for industry: chronic cutaneous ulcer and burn wounds – developing products for treatment (draft guidance). FDA: CBER, CDRH, CDER. June. 2000. (http://www.fda.gov/cber/gdlns/ulcburn.pdf). accessed November 28, 2004.
6 Fine NA, Mustoe TA. Greenfield LJ, editor. Wound Healing. Surgery: Scientific Principles and Practice. 3rd Edition. Philadelphia. JB Lippincott Co. 2001:67-82.
7 Gibbons GW, Marcaccio EJ, Havershaw GM. Management of the diabetic foot in Callow AD. Ernst CB Vascular Surgery: Theory and Practice. Stamford. Appleton and Lange. 1995.
8 O’Donnell TF, Rosenthal DA, Callow AD. The effect of elastic compression on venous hypertension in post phlebetic limbs. JAMA. 1979;242:2766-2768. [pmid: 501883].
9 O’Donnell TF. Chapter 28. Chronic Venous Insufficiency and Varicose Veins in Young JR, Olin JW, Bartholomen JR. Peripheral Vascular Diseases. St. Louis. Mosby. 1996.
10 Nehler MR, Moneta GL, Woddard DM, et al. Perimalleolar subcutaneous pressure effects of elastic compression stockings. J Vasc Surg. 1993;17:431.
11 Winter CD. Formation of the scab and the rate of epithelialization of superficial wounds in the skin of the young domesticated pig. Nature. 1962;193:293-294. [pmid: 14007593].
12 Hinman ED, Maibach MI, Winter CD. Effect of air exposure and occlusion on experimental skin wounds. Nature. 1963;200:377-379. [pmid: 14087904].
13 Falanga V. Occlusive Wound Dressings: Why, When, What. Arch Dermat. 1988;124:876-879.
14 British National Formulary. British Medical Association and the Royal Pharmaceutical Society of Great Britain. 1998:35.
15 Agency for Health Care Policy and Research (AHCPR). Treatment of pressure ulcers. Rockville (MD): U.S. Department of Health and Human Services, Public Health Service, AHCPR. Dec. 1994:154. p. (Clinical practice guideline; no. 15).
16 American Medical Directors Association (AMDA). Pressure ulcers. Columbia (MD). American Medical Directors Association. 1996:16.
17 American Medical Directors Association. Pressure ulcer therapy companion. Columbia (MD). American Medical Directors Association. 1999:35.
18 Folkedahl BA, Frantz R. Treatment of pressure ulcers. Iowa City (IA). University of Iowa Gerontological Nursing Interventions Research Center, Research Dissemination Core. Aug. 2002:30.
19 Frykberg RG, Armstrong DG, Giurini J, Edwards A, Kravette M, Kravitz S, Ross C, Stavosky J, Stuck R, Vanore J. Diabetic foot disorders: a clinical practice guideline. American College of Foot and Ankle Surgeons. J Foot Ankle Surg. 2000;39(5 Suppl):S1-S60. [pmid: 11280471].
20 New Zealand Guidelines Group. Primary care guidelines for the management of core aspects of diabetes care. Wellington (NZ). New Zealand Guidelines Group (NZGG). Jun. 2000:19.
21 Paralyzed Veterans of America. Pressure ulcer prevention and treatment following spinal cord injury: A clinical practice guideline for health care professionals. Washington (DC). Paralyzed Veterans of America. Aug. 2000:94.
22 Registered Nurses Association of Ontario (RNAO). Assessment and management of stage I to IV pressure ulcers. Toronto (ON). Registered Nurses Association of Ontario (RNAO). Aug. 2002:104.
23 Singapore Ministry of Health. Nursing management of pressure ulcers in adults. Singapore. Singapore Ministry of Health. Dec. 2001:27.
24 Wound Ostomy and Continence Nurses Society (WOCN). Guideline for management of wounds in patients with lower-extremity arterial disease. Glenview (IL). Wound Ostomy and Continence Nurses Society (WOCN). Jun. 2002:44. (WOCN clinical practice guideline series; no. 1).
25 Wound, Ostomy, and Continence Nurses Society (WOCN). Guideline for prevention and management of pressure ulcers. Glenview (IL). Wound, Ostomy, and Continence Nurses Society (WOCN). 2003:52. (WOCN clinical practice guideline; no. 2).
26 Mani R, editor. Chronic wound management: the evidence for change. Boca Raton. Parthenon Publishing Group. 2003.
27 Rakel RE, editor. Textbook of family practice. 6th ed. Philadelphia: W.B. Saunders. 2002.
28 Norton JA, editor. Surgery: basic science and clinical evidence. New York. Springer. 2001.
29 Schwartz SI, editor. Principles of surgery. 7th ed. New York. McGraw-Hill. 1999.
30 Fry DE, editor. Surgical infections. Boston. Little Brown. 1995.