# RESULTS

The MEDLINE search yielded a total of 1,575 citations. After reviewing the abstracts, we retrieved 146 full articles for further evaluation. Thirty-nine studies that met the final inclusion criteria are summarized in this report. Six randomized controlled trials (RCTs) involving 541 patients and 24 prospective and 10 retrospective cohort studies with about 25,000 patients reported on deaths and other outcomes. Data from these studies are shown in Evidence Tables 1–4 in the appendix.

We describe in this section the results of the studies grouped by 3 levels of PaO_2_ (mmHg): ≤ 55, 56 – 59, and 60 – 64. Within each of the PaO_2_ levels, mortality results are presented first followed by other outcomes. Table 1 below summarizes the number of studies and outcomes available in each of the PaO_2_ levels.

Table 1 Studies of LTOT for COPD Patients Included in this Report

| RCTs # studies (# patients) | | Cohort Studies # studies (# patients)
Population PaO_2_ mmHg | Mortality | Other Outcomes | Mortality | Other Outcomes
≤ 55 | 2 (n=290) NOTT 1980 MRC 1981 | Hospital admission 2 (n=290) NOTT 1980 MRC 1981 HRQL 1 (n=203) NOTT 1980, 1983 Exercise capacity 1 (n=10) Cuvelier 2002 Pulmonary function 3 (n=320) Fleetham 1980 NOTT 1980 MRC 1981 | 17 prospective cohorts (n=6,723) Krop 1973 Ashutosh 1983 Weitzenblum 1985 Vergeret 1989 Gorecka 1992 Dubois 1994 Dallari 1994 Simonds 1995 Oswald-Mammosser 1995 Borak 1996 Clini 1996 Okubadejo 1996 Heaney 1997 Aida 1998 Strom 1998 Zielinski 1998 Farrero 2001 8 retrospective cohorts (n=18,300) McKeon 1987 Corrado 1994 Buyse 1995 Miyamoto 1995 Chailleux 1996 Hjalmarsen 1999a Crockett 2001 Demirel 2003 | Hospital admission 4 (n=319) Stewart 1975 Weitzenblum 1985 Clini 1996 Ringbaek 2002 HRQL 6 (n=223) Krop 1973 Lahdensuo 1989 Borak 1996 Okubadejo 1996 Hjalmarsen 1999b Farrero 2001 Sleep 1 (n=12) Lin 1996 Pulmonary function 8 (n=200) Krop 1973 Weitzenblum 1991 Simonds 1995 Clini 1996 Okubadejo 1996 Farrero 2001 Sergi 2002 Bratel 2003
56 – 59 | ND | ND | prospective cohorts 1 (n=46) Sliwinski 1992 | Pulmonary function 1 (n=14) Sandek 2001 Hospital admission 1 (n=46) Sliwinski 1992
60 – 64 | 2 (n=211) Gorecka 1997 Chaouat 1999 | Pulmonary function 1 (n=76) Chaouat 1999 | retrospective cohorts 1 (n=48) Hjalmarsen 1999a | ND

ND – no data

HRQL – health related quality of life

## Patients with PaO_2_ ≤55 mmHg

Two RCTs enrolled 290 COPD patients with PaO_2_ ≤ 55 treated with LTOT reported data on mortality outcomes (NOTT 1980, MRC 1981). Seventeen prospective cohort studies with a total of 6,723 COPD patients with PaO_2_ ≤ 55 treated with LTOT reported mortality data (Table 2).

### Mortality Outcomes - RCTs

The Nocturnal Oxygen Therapy Trial (NOTT) selected 203 patients from 1,043 patients with hypoxemic COPD evaluated in 6 centers (NOTT 1980). One hundred and two patients were randomized to receive nocturnal oxygen therapy (NOT) and 101 patients to continuous oxygen therapy (COT). Patients were randomized in blocks of 4 within each study center. Neither the investigators nor the patients were blinded. Oxygen was delivered via nasal prongs using oxygen concentrators, liquid oxygen systems, or compressed gas. Patients were evaluated at baseline and every 6 months thereafter.

Seventy-nine percent of the patients were male and the average age was 65 years. The baseline general and cardiopulmonary characteristics were well balanced between the study groups with mean PaO_2_ of 51.5 mmHg in the NOT group and 50.8 mmHg in the COT group, mean PaCO_2_ of 43 mmHg and % predicted FEV_1_ of 30 in both groups. The overall baseline rating of the neuropsychiatric characteristics was higher in the NOT group compared with the COT group (4.5 vs. 4.2) and was marginally significant (P=0.06).

Surviving patients were followed for a minimum of 12 months with a mean of 19 months. Adherence to oxygen therapy was noted to be “very good”. Patients in the COT group received an average of 18 hours and patients in the NOT group received 12 hours of oxygen therapy daily. Overall, 21 patients died in the COT group and 41 patients died in the NOT group. The 12-month mortality was 12% in the COT group and 21% in the NOT group (odds ratio 0.53, 95% CI 0.25–1.11). At 24 months, the mortality was 22% in the COT group and 41% in the NOT group (odds ratio 0.45, 95% CI 0.25–0.81).

The Medical Research Council trial from UK randomized 87 patients in 3 centers to receive LTOT or no placebo/supplemental-oxygen controls (MRC 1981). Oxygen was administered via nasal prongs using oxygen concentrators, liquid oxygen systems or oxygen cylinders for at least 15 hours/day in the treatment group. Neither the investigators nor the patients were blinded.

Forty-two patients were randomized to LTOT and 45 patients served as no-treatment controls. The average age was 58 and 76% of the patients were men. The mean baseline PaO_2_ measurements of the 2 groups were similar (50.2 mmHg in the LTOT group vs. 51.6 mmHg in the control group). The mean baseline FEV_1_ in men who received LTOT was slightly higher than the control (0.76 L vs. 0.65 L). Although the mean baseline PaCO_2_ was similar between groups (55 mmHg), this was higher than that of the NOTT study population (43 mmHg).

During a 5-year follow up, 19 of the 42 patients (45%) on LTOT died, compared with 30 of the 45 controls (67%) (odds ratio 0.42, 95% CI 0.18–0.98). The benefit for men was not seen until after 500 days whereas the benefit for women was demonstrated almost immediately. One patient was withdrawn from the LTOT group due to failure to comply.

The patients in both trials were mostly similar and they achieved similar degree of mortality reduction. However, the control group in the NOTT trial used NOT whereas the control group in MRC trial had no supplemental oxygen. While one can conclude that at least 15 hours of COT is beneficial, one cannot directly infer that there is a continuous dose effect (i.e., whether 18 hours of COT is better than 15 hours or whether 12 hours of NOT is better than no supplemental oxygen).

Table 2 Cohort studies that reported mortality data of LTOT for COPD patients with PaO_2_ ≤ 55 mmHg

Study Year Country | Study Size | Study duration (years) | Mortality %
Study Year Country | Study Size | Study duration (years) | 1 y | 2 y | 3 y | 5 y
Prospective Cohort Studies
Aida 1998 Japan | 4,552 | 6 | 12 | 38 | | 61
Strom 1991, 1993, 1998 Sweden | 405 | 2.3 | 23 | 44 | | 62
Gorecka 1992 Poland | 315 | 1 | 21
Dubois 1990 1994 Belgium | 270 | 3 | 30 | 50 | 57 | 83
Heaney 1997 N Ireland | 178 | > 8 | 31 (10 mo) | 50 (20 mo) | | 67
Dallari 1994 Italy | 166 | 2 | | 22 | 33
Borak 1996 Poland | 1224 | 1 | 27
Zielinski J 1998 Poland | 95 | 6 | | 23
Oswaldmammosser 1995 France | 84 | 5 | | | 29 | 52
Vergeret 1989 Denmark | 75 | 2 | 12
Farrero 2001 Spain | 62 | 1 | 34
Simonds 1995 England | 33 | 5 | 15 | 24 | 32 | 55
Okubadejo 1996 UK | 23 | 0.5 | 17 (6 mo)
Clini 1996 Italy | 34 | 1.5 | 17–23
Ashutosh 1983 USA | 28 | 2 | | Responders 13 (n=17) Non-responders 78 (n=11)
Weitzenblum 1985 1991 France | 24 | 1 | | | 25 (33 mo, n=16) | 65 (73 mo)
Krop 1973 Stewart 1975 US | 12 | 2 | 8.3 | 33
Retrospective Cohort
Chailleux 1996 2003 France | 12,403 | 10 | ~25 | ~41 | ~70
Miyamoto 1995 | 5,055 | 7 | ~13 | ~25 | ~36 | ~58
Crockett 2001 Australia | 505 | 10 | 25 | 49 | | 81
Demirel 2003 Turkey | 127 | 1.4 | 5.5
McKeon 1987 Australia | 84 | 14 | 6 | 20 | | 64
Corrado 1994 Italy | 35 | 4 | ~6 | ~17 | ~37 | ~49 (4 y)
Hjalmarsen 1999a Sweden | 76 | 8 | | 27 | | 50
Buyse 1995 Belgium | 15 | 3 | 13 | 40

### Mortality Outcomes - Cohort Studies

Seventeen prospective cohort studies were conducted in Australia, Europe, Japan, and the US (Table 2). These studies included a total of 6,723 patients with study size ranging from 12 to 4,552. The studies followed patients from 6 months to 12 years. LTOT therapy was generally given 14 to 24 hours daily. One study reported greater than 8 hours of oxygen at night and 1 study did not report oxygen usage data. The reported mortality varies between 6 to 34% at 1 year of follow-up in 12 studies, 20 to 50% at 2 years in 9 studies, 25 to 57% at 3 years in 5 studies, and 52 to 83% at 5 years in 7 studies. The largest prospective cohort study of 4,552 patients came from Japan with a mean follow up of 2.4 years (Aida 1998). They reported 1-, 2-, and 5-year mortality of 12, 38, and 61%, respectively.

Eight retrospective cohort studies with 6 months to 10 years of follow-up reported mortality outcomes in 18,300 patients (Table 2). Four studies reported patients were prescribed at least 15 hours of oxygen daily while the other 4 studies did not report this information. The range of mortality rates of the retrospective cohort studies at different follow-up time points are similar to those of the prospective cohort studies. The largest retrospective cohort study with 12,403 patients from France reported 1-, 2-, and 3-year mortality rates of 25, 41, and 70%, respectively (Chailleux 1996). The second largest retrospective cohort study of 5,055 patients was conducted in Japan (Miyamoto 1995). This study reported 1-, 2-, 3- and 5-year mortality rates of 13, 25, 36, and 58%, respectively. This study shared the same patient registry as the report by Aida et al. (1998) and probably had a large degree of overlap in the patients studied.

### Other (non-mortality) Outcomes

#### Hospital Admission - RCTs

Two RCTs reported results on hospitalization. The NOTT and MRC trials both reported that LTOT decreases the number of days of hospitalization among hypoxemic COPD patients although neither trial reported results numerically. The NOTT study reported that patients on COT tended to be hospitalized less often and to have fewer long hospitalizations than NOT patients, although differences were not statistically significant (NOTT 1980). The MRC trial reported that the duration of hospitalization due to exacerbations of respiratory failure was not affected by oxygen therapy (MRC 1983).

#### Hospital Admission – Cohort Studies

Three prospective (Krop 1973, Weitzenblum 1985, Clini 1996) and 1 retrospective (Ringbaek 2002) cohort studies reported hospitalization data. All of these studies reported that LTOT reduced the frequency of hospitalization and the number of hospital days. Krop et al. (1973) reported that the average number of days hospitalized per patient decreased from about 30 days before LTOT to 20 days 1 year after LTOT oxygen was instituted in a cohort of 12 patients. In a cohort of 16 patients, Weitzenblum et al. (1985) reported that the average number of hospitalization days per year decreased from 18 to 9 after LTOT. Clini et al. (1996) compared two 18-month periods before and after LTOT in a cohort of 17 patients. They reported that the average number of hospital admissions decreased from 2 to 1 and the average number of days in hospital decreased from 55 to 18 after LTOT. In a retrospective cohort study of 246 patients that focused on the effect of LTOT on hospitalization, Ringbaek et al. (2002) reported that the average number of hospital admissions per patient per year decreased from 2.1 to 1.6 and he average number of days hospitalized decreased from 23.7 to 13.4 after LTOT. Similar magnitude of decreases were seen in patients who received 15–24 hours of oxygen daily compared with those who received less than 15 hours.

#### Health Related Quality of Life (HRQL) and Neuropsychological - RCT

The NOTT study was the only RCT that reported HRQL data. It assessed Minnesota Multiphasic Personality Inventory (MMPI) scale, Sickness Impact Profile (SIP) and Profile of Mood States (NOTT 1980). The study reported neuropsychological deficits in hypoxemic COPD patients and observed small (“average about 10%”) improvements in neuropsychological function and quality of life scores when data from patients receiving COT or NOT were combined. The authors hypothesized that these small changes might have been due to the more intensive medical and nursing care that the patients received as study participants rather than the direct effect of oxygen. Numerical data for HRQL measures were reported for the baseline but not for the end of the trial.

#### Health Related Quality of Life (HRQL) and Neuropsychological – Cohort Studies

Six prospective cohort studies reported HRQL or neuropsychological outcomes on 223 patients (Krop 1973, Lahdensuo 1989, Borak 1996, Okubadejo 1996, Hjalmarsen 1999b, Farrero 2001). LTOT was provided for various durations from 3 months to 2 years in these studies. These studies reported HRQL and psychological and psychosocial response data, including: MMPI, Wechsler Adult Intelligence Scale, Wechsler Memory Scale, Bourdon-Wiersma Test, Beck Depression Inventory, Chronic Respiratory Questionnaire, St. George’s Respiratory Questionnaire, SIP and the Hospital Anxiety and Depression Scale (HADS).

The study by Borak et al. (1996) from Poland reporting data on 90 patients represents the largest cohort of COPD patients with PaO2 ≤ 55 mmHg that have been evaluated for neuropsychological status before and after the initiation of LTOT. Of the 124 initially eligible patients, cognitive function, psychological status, and attitudes were assessed before and after one year in 90 survivors using a battery of instruments. The authors found major cognitive dysfunction and severe emotional disturbances at baseline. Patients were found to have a low level of concentration, narrow interests, reduced planning ability, disturbed direct memory, and reduced visual/spatial coordination. After one year of oxygen therapy, improvements in cognitive function were limited to recent memory and speed of work. A significant improvement in self-esteem and emotional status were observed following treatment. It was noted that improvements in psychological status was observed despite some deterioration in pulmonary function. The authors also concluded that it is difficult to separate the effect of oxygen from the overall benefits of specialist medical care.

Two other small studies of 12 patients (Krop 1973) and 10 patients (Hjalmarsen 1999b) also reported that LTOT is associated with an improvement in intellectual functioning, depression and HRQL. The changes observed in these studies did not reach statistical significance due to the small study size. However, 3 other studies with a total of 111 patients) reported that there was no significant change in the HRQL and psychological and psychosocial variables in patients treated with LTOT (Lahdensuo 1989, Okubadejo 1996, Farrero 2001.

#### Sleep Outcomes

We identified only 1 prospective cohort study that investigated the effect of LTOT on sleep (Lin 1996). The study was conducted in Taiwan on 12 patients with severe COPD. Total sleep time, sleep efficiency, and sleep latency were compared before therapy and after 2 weeks of oxygen therapy. The study found that sleep efficiency and sleep architecture did not change with oxygen therapy.

#### Exercise Capacity

One randomized crossover study of 10 COPD patients on LTOT reported physical exercise capacity outcome (Cuvelier 2002). The patients performed 3 successive 6-min walking tests separated by 60 minutes of rest. The first test was conducted in room air and the other tests in a random order with 2 types of refillable oxygen cylinders. Mean walking distance was significantly increased when performed with either cylinders (375±97 meters [p=0.02] or 374±81 meters [p=0.03]) compared with room air (335±90 meters).

#### Pulmonary Function and Physiologic Measurements – RCTs

Three RCTs (Fleetham 1980, NOTT 1980, MRC 1981) reported on pulmonary function and physiologic measurements. Fleetham randomized 30 COPD patients to treatment with either 12 hours of NOT or 24 hours of COT (Fleetham 1980). There were no significant changes in pulmonary function (FEV_1_%) in either group over the 6 months period. Among patients who received LTOT in the MRC trial, the red cell mass fell slightly and the mean PAP remains unchanged, whereas in the control group the red cell mass and the PAP rose. These changes were not significantly different between groups. The NOTT study reported that in patients who received COT, comparing with patients who received NOT, the pulmonary vascular resistance was significantly decreased at 6 months (−11% vs. +6.5%; p=0.04). Hematocrit was also significantly decreased in the COT group when compared with the NOT group (9.2 % vs. 2%, p=0.008).

#### Pulmonary Function and Physiologic Measurements – Cohort Studies

Eight prospective cohort studies (Krop 1973, Weitzenblum 1985, Simonds 1995, Clini 1996, Okubadejo 1996, Farrero 2001, Sergi 2002, Bratel 2003) reported pulmonary function data on 218 patients. No significant changes were reported in FEV_1_% in 5 studies (Krop 1973, Weitzenblum 1985, Simonds 1995, Clini 1996, Okubadejo 1996) while 2 other studies (Farrero 2001, Sergi 2002) found significant improvements in FEV_1_%. Bratel reported a non-significant decrease in hemoglobin (15.1 g to 14.6 g) and no change in FEV_1_% in 12 patients.

## Patients with PaO_2_ between 56 and 59 mmHg

### Mortality Outcomes

There was no RCT in this category of PaO_2_. One prospective cohort study of 46 COPD patients with mean PaO_2_ of 57 mmHg investigated whether the acute effect of oxygen on pulmonary arterial pressure (PAP) is related to survival (Sliwinski 1992). Patients who experienced a decrease of 5 mmHg or more of PAP while breathing supplemental oxygen were classified as responders. After 2 years of LTOT, 12 patients died in the non-responders group (39 patients) and 3 died in the responders group (7 patients). The 2-year survival rate was 69% in non-responders and 57% in responders.

### Hospital Admission

The study by Sliwinski (1992) also assessed the relationship of responders to LTOT (based on PAP changes) with hospitalization. After 2 years of LTOT, the subjects from the non-responders group were admitted to the hospital 55 times versus 6 times in the responders group during the study period of 2 years. On average there were 1.4 versus 0.8 admissions per patient in the non-responders versus responders group.

### Pulmonary Function and Physiologic Measurements

We found 1 prospective cohort studies in this category of PaCO_2_ reporting the effect of LTOT on pulmonary function and physiological measurements. In a study of 14 COPD patients receiving 6 months of LTOT (Sandek 2001), no significant changes in dynamic or static lung volumes, hypercapnic ventilatory response or hypercapnic drive response were detected. The author concluded that 6 months of low flow oxygen therapy in stable COPD patients is not accompanied by any clinically important changes in pulmonary physiology.

## Patients with PaO_2_ between 60 and 64 mmHg

### Mortality Outcomes - RCT

Two RCTs reported mortality outcomes in this category of PaO_2_. One RCT evaluated 76 COPD patients in 6 hospitals in 4 European countries (Chaouat 1999). Forty-one patients were randomized to oxygen concentrator for 8–10 hours per night and 35 patients to no oxygen control group. There was no significant difference in mortality between the treated and control groups on an intention to treat analysis (odds ratio 1.1, 95% CI 0.37–3.4). The second trial randomized 135 patients into LTOT (at least 17 hours of oxygen daily) or usual care (Gorecka 1997). The patients were followed for 3 years or until death. No significant difference in mortality was found between the 2 groups (odds ratio 1.1, 95% CI 0.37–3.4).

### Mortality Outcomes - Retrospective cohort

Hjalmarsen et al. (1999a) analyzed a retrospective cohort of 124 patients using LTOT for 6 years by dividing it into 2 groups with PaO_2_ ≤ 55 mmHg and PaO_2_ ≥ 56 mmHg (mean PaO_2_ = 62 mmHg). Both groups had similar FEV_1_ and FVC levels. The 2- and 3-year survival rates were 73% and 50%, respectively, in the PaO_2_ ≤ 55 group, and 78% and 40% in the PaO_2_ ≥ 56 group. The author concluded that survival during LTOT was similar in patients with and without severe hypoxemia at the same level of loss of lung function.

### Pulmonary Function and Physiologic Measurements

The RCT by Chaouat (1999) also collected pulmonary function and physiologic measurements. It reported no significant changes in FEV_1_, resting and exercising PAP between LTOT and control groups.

## Adverse Effects of LTOT

Two studies reported adverse effects and safety concerns with the use of LTOT. One study reported: “A negative psychological impact on the patients caused by the oxygen treatment was reported in a small proportion of the follow-up recordings (0–9%)” (Strom 1991). However, this issue was not expanded upon in the article.

One retrospective review of burn patients reported a subgroup of 23 LTOT patients with burn injuries directly related to use or handling of oxygen (Chang 2001). In this study, COPD was the most prevalent reason for home oxygen use (20 of the 23 patients). The mean age was 70 years with a range of 50 to 84 years. Causes of fire included cigarette smoking (16/23), cooking (6/23), and refilling a home oxygen unit with liquid oxygen (1/23). Twenty-one of 23 sustained partial-thickness injuries involving an average of 4% of the body surface area. Inhalation injury occurred in 13 patients with 5 of them requiring tracheal incubation and mechanical ventilation because of a combination of direct inhalation injury, acute worsening of their underlying pulmonary disease, and subsequent lung infection. Two of the 23 patients died during their hospitalizations. Both were injured while smoking during the use of their home oxygen.