# METHODS

We conducted a systematic review of the literature to identify clinical studies in humans to address the above issues. The research questions could be succinctly rephrased as: What is the evidence on the outcomes and adverse effects in COPD patients treated with LTOT? In consultation with representatives from AHRQ, CMS, and NHLBI, we developed the following literature review criteria. These criteria include specifications of design, patient population/disease characteristics, types of LTOT and comparators, and outcomes of the studies to be reviewed.

## Inclusion Criteria for Outcomes Studies

We accepted studies that reported the evaluation of LTOT in hypoxemic COPD patients on relevant outcomes of interest. Specific criteria for the patient population, interventions, outcomes, and study designs are discussed below.

### Hypoxemic COPD Patients

We included LTOT studies of adult COPD patients based on 3 levels of hypoxemia: PaO_2_ (mmHg) ≤ 55, 56 – 59, and 60 – 64. We accepted the definition of COPD as defined by the study authors, this generally included patients with chronic bronchitis and emphysema. FEV_1_ or % of predicted FEV_1_ were not used as an entry criterion in our report. Studies that used the inclusion criteria of PaO_2_ ≤ 55 mmHg also typically included patients with PaO_2_ between 56 and 59 if they demonstrated evidence of tissue hypoxia. We included cohort studies that evaluated mixed population (e.g., cancer, heart failure) if they reported stratified data for COPD patients or if at least 80% of the patients have COPD at hypoxemic levels of our interest.

### Long-term Oxygen Therapy

LTOT is the use of oxygen outside the hospital setting in patients with COPD who are otherwise medically stable. Oxygen can be given while the patient is at rest, ambulating or sleeping at night. Oxygen may be delivered to the patient via nasal cannula, facemask, non-invasive positive pressure ventilation, or through the transtracheal route. It is generally accepted that patients who meet the criteria for LTOT should receive continuous supplemental oxygen 24 hours per day. However, the minimum number of hours of oxygen use needed to qualify for LTOT is not well defined. In addition, the number of hours of actual use of LTOT each day is dependent on patient adherence. For the purpose of this report we included all studies that were defined by the study authors as LTOT, including studies that used nocturnal oxygen only. We included studies that provided oxygen using refillable cylinders, concentrators, or liquid oxygen systems.

### Outcomes

Outcomes assessed in this report included survival and non-survival outcomes. Non-survival outcomes include: hospitalization episodes, length of stay, quality of life, exercise capacity, neuro-cognitive outcomes, depression, changes in pulmonary function (e.g., FEV_1_) and other physiologic measurements (e.g., pulmonary artery pressure, hematocrit), and progression of pulmonary hypertension (cor pulmonale). In consultation with NHLBI staff, PaO_2_ and PaCO_2_ were not included as outcomes of interest.

### Study Design

We included randomized controlled trials (RCTs) to provide direct comparisons of LTOT with standard care or alternative interventions. Prospective and retrospective cohorts (including LTOT patients registries) of patients using LTOT are used to derive additional information about survival and to compare baseline with follow-up results of various endpoints. For mortality outcomes, the percentages of mortality or survival at defined time periods in the cohort were extracted. To qualify for evidence to be used for non-survival outcomes, cohort studies must report either results at baseline and at follow-up, or results of a defined comparison group. The LTOT arm of a RCT that do not meet the inclusion criteria (e.g., the main purpose of a study was to compare modes of oxygen delivery rather than the effects of LTOT) may nonetheless be included as a prospective cohort to provide additional information on survival and other outcomes. To be considered, each study must have at least 10 patients in each study arm (i.e., 10 in a cohort study and 20 in a parallel group randomized trial). To be considered for survival outcome, a study must have followed patients for at least 6 months.

## Inclusion Criteria For Adverse Effect Studies

We accept adverse effects data in all the studies evaluated for clinical outcomes and any study that explicitly reported on adverse effects attributed to oxygen use. We excluded adverse effects related to oxygen delivery methods (e.g., complications of transtracheal method).

## Excluded Studies

We excluded studies in which the main purpose was the evaluation of LTOT in patients with kyphoscoliosis or obesity-related obstructive sleep apnea, comparisons of different forms of oxygen delivery systems, or the evaluation of other interventions without outcomes specific to LTOT arms. Cross-sectional studies that do not provide longitudinal follow-up data for comparisons are excluded.

Several sets of articles were publications on the same or overlapping populations. From each set, we selected the article with the most comprehensive reporting of data and used other articles for supplemental information.

## Literature search

We performed a MEDLINE search on February 27, 2004 for English language studies that evaluated the use of LTOT in patients with COPD. Search terms related to “long-term” included: ambulatory, continuous, domiciliary, home, long-term, and nocturnal. In addition, we reviewed the references of published systematic reviews, retrieved clinical trial articles, selected review articles, and clinical practice guidelines on this topic for potentially relevant studies.

## Evidence Tables

Data extracted from each study that met the review criteria are summarized in evidence tables included in the appendix of this report. The evidence tables provide information for each of the studies on selected baseline patient characteristics, inclusion and exclusion criteria, study design, intervention, comparator, and outcomes. Evidence tables are grouped according to their study designs (randomized controlled trials or cohort studies) and then according to the 3 PaO_2_ levels. Within each evidence table, the studies are ordered chronologically in ascending order according to their publication year.