# CONCLUSIONS

Evidence from RCTs to guide the use of LTOT in patients with COPD is very limited. Most of the studies included in this report focused on the severely hypoxemic populations with PaO_2_ ≤ 55 mmHg. Only 2 RCTs published over 20 years ago evaluated patients with PaO_2_ between 56 and 59 mmHg. Both of these trials reported similar reduction of overall mortality. Two RCTs conducted in patients with PaO_2_ between 60 and 64 mmHg reported no mortality benefits.

Twenty-five prospective or retrospective cohort studies with almost 25,000 patients reported survival data for COPD patients with PaO_2_≤55. It can be readily appreciated from these cohort studies that the overall survival in the severely hypoxemic population on LTOT is poor, compared with the normal population. The survival rates at any common time point varied widely across the studies suggesting that large variations exist in the inclusion criteria, populations studied, forms of intervention, and assessment of outcomes. This degree of heterogeneity and the lack of a comparison group make it difficult to generalize the results of individual studies.

Limited evidence from RCTs and cohort studies on non-mortality outcomes in patients with PaO_2_ ≤ 55 mmHg suggest that LTOT may reduce the number of hospital admission or the length of hospitalization, improve certain aspects of neuropsychological function.

Serious adverse effect appears to be limited to the well-known problem that oxygen is highly flammable and should not be used around open flames. Occasional thermal burn injuries may also occur with handling of liquid oxygen systems.

It is unnecessary to conduct additional placebo controlled RCTs in patients with PaO_2_ ≤55 mmHg. However, there is currently no randomized evidence of survival benefit in patients with PaO_2_ 56–59 mmHg. The methodological quality of the studies could be substantially improved. Better standardization of inclusion criteria and outcome measures will facilitate the interpretation of results across studies. Several studies have analyzed clinical and physiologic measures as predictors of responses to survival and non-survival benefits in LTOT users. A priori stratification by potential predictors of outcomes might be useful to gain insights to optimize management.