# List of Rejected Articles

## Reject List

1 Abdulla J, Godtfredsen N, Pisinger C, Wennike P, Tonnesen P. Adequacy of oxygenation in a group of Danish patients with COPD on long-term oxygen therapy. Monaldi Archives for Chest Disease. 2000;55(4):279-282. [pmid: 11057078]. No baseline data
2 Ambrosino N, Clini E. Noninvasive ventilation in COPD patients with chronic respiratory failure--pro. Monaldi Archives for Chest Disease. 2000;55(1):54-57. [pmid: 10786427]. Review/report
3 Andersson I, Johansson K, Larsson S, Pehrsson K. Long-term oxygen therapy and quality of life in elderly patients hospitalised due to severe exacerbation of COPD. A 1 year follow-up study. Respiratory Medicine. 2002;96(11):944-949. [pmid: 12418593]. QOL not stratified by tx / non_tx groups
4 Anon JM, Garcia dL, Zarazaga A, GomezTello V, Garrido G. Mechanical ventilation of patients on long-term oxygen therapy with acute exacerbations of chronic obstructive pulmonary disease: prognosis and cost-utility analysis. Intensive Care Med. 1999;25:452-457. [pmid: 10401937]. Not population of interest
5 Bellone A, Venanzi D, De Angelis G, Adone R, Aliprandi P, Castelli C, et al. Who should prescribe long-term oxygen in patients affected by chronic arterial hypoxaemia?. Monaldi Archives for Chest Disease. 1994;49(5):396-398. [pmid: 7841975]. No outcomes of interest
6 Berg J. Quality of life in COPD patients using transtracheal oxygen. MEDSURG Nursing. 1996;5(1):36-40. [pmid: 8696406]. n<10, no outcomes of interest
7 Birnbaum ML, Cree EM, Rasmussen H, Lewis P, Curtis JK. Effects of intermittent positive pressure breathing on emphysematous patients. American Journal of Medicine. 1966;41(4):552-561. [pmid: 5332298]. Not LTOT
8 Bloom BS, Daniel JM, Wiseman M, Knorr RS, Cebul R, Kissick WL. Transtracheal oxygen delivery and patients with chronic obstructive pulmonary disease. Respiratory Medicine. 1989;83(4):281-288. [pmid: 2692091]. Not LTOT, comparison of delivery methods
9 Bonsignore G. Nocturnal desaturation in patients with bronchitis and emphysema. European Journal of Respiratory Diseases - Supplement. 1983;126:291-294. [pmid: 6586443]. Not LTOT
10 Booth S, Anderson H, Swannick M, Wade R, Kite S, Johnson M, et al. The use of oxygen in the palliation of breathlessness. A report of the expert working group of the Scientific Committee of the Association of Palliative Medicine. Respiratory Medicine. 2004;98(1):66-77. [pmid: 14959816]. Guideline/report
11 Borak J, Sliwinski P, Piasecki Z, Zielinski J. Psychological status of COPD patients on long term oxygen therapy. European Respiratory Journal. 1991;4(1):59-62. [pmid: 2026240]. No baseline data
12 Boysen PG. Nocturnal oxygen therapy and hemodynamic changes in COPD. Chest. 1984;85(1):2-3. [pmid: 6690248]. Report/abstract
13 Brambilla I, Arlati S, Micallef E, Sacerdoti C, Rolo J. A portable oxygen system corrects hypoxemia without significantly increasing metabolic demands. American Review of Respiratory Disease. 1985;131(1):51-53. [pmid: 3917632]. n<10
14 Burns HL, Ralston D, Muller M, Pegg S. Cooking and oxygen. An explosive recipe. Australian Family Physician. 2001;30(2):138-140. [pmid: 11280113]. Case report, not relevant
15 Calverley PM, Leggett RJ, McElderry L, Flenley DC. Cigarette smoking and secondary polycythemia in hypoxic cor pulmonale. American Review of Respiratory Disease. 1982;125(5):507-510. [pmid: 7081807]. n<10
16 Cano NJ, Roth H, CourtOrtune I, Cynober L, GerardBoncompain M, Cuvelier A, et al. Nutritional depletion in patients on long-term oxygen therapy and/or home mechanical ventilation. European Respiratory Journal. 2002;20(1):30-37. [pmid: 12166577]. No outcome of interest
17 Carter R, Tashkin D, Djahed B, Hathaway E, Nicotra MB, Tiep BL. Demand oxygen delivery for patients with restrictive lung disease. Chest. 1989;96(6):1307-1311. [pmid: 2582836]. n<10 per arm
18 Casanova C, Celli BR, Tost L, Soriano E, Abreu J, Velasco V, et al. Long-term controlled trial of nocturnal nasal positive pressure ventilation in patients with severe COPD.[see comment]. Chest. 2000;118(6):1582-1590. [pmid: 11115443]. Not population of interest, Not LTOT
19 Chaouat A, Weitzenblum E, Kessler R, Schott R, Charpentier C, LeviValensi P, et al. Outcome of COPD patients with mild daytime hypoxaemia with or without sleep-related oxygen desaturation. European Respiratory Journal. 2001;17(5):848-855. [pmid: 11488315]. Not LTOT, n<10
20 Chiang LL, Hung TC, Ho SC, Lin HC, Yu CT, Wang CH, et al. Respiratory response to carbon dioxide stimulation during low flow supplemental oxygen therapy in chronic obstructive pulmonary disease. Journal of the Formosan Medical Association. 2002;101(9):607-615. [pmid: 12645187]. Not LTOT
21 Cornford CS. Lay beliefs of patients using domiciliary oxygen: a qualitative study from general practice. British Journal of General Practice. 2000;50(459):791-793. [pmid: 11127167]. Qualitative research
22 Corriveau ML, Rosen BJ, Dolan GF. Oxygen transport and oxygen consumption during supplemental oxygen administration in patients with chronic obstructive pulmonary disease. American Journal of Medicine. 1989;87(6):633-637. [pmid: 2589398]. Not LTOT
23 Crockett AJ, Cranston JM, Moss JR, Alpers JH. A review of long-term oxygen therapy for chronic obstructive pulmonary disease. Respiratory Medicine. 2001;95(6):437-443. [pmid: 11421499]. Review
24 Dal Nogare AR, Rubin LJ. The effects of hydralazine on exercise capacity in pulmonary hypertension secondary to chronic obstructive pulmonary disease. American Review of Respiratory Disease. 1986;133(3):385-389. [pmid: 3954247]. Not LTOT
25 Damato S, Frigo V, Dell'Oca M, Negretto GG, Tarsia P. Utility of monitoring breathing during night hours in COPD patients undergoing long-term oxygen therapy. Monaldi Archives for Chest Disease. 1997;52(2):106-111. [pmid: 9203804]. Not LTOT, no outcomes of interest
26 Dardes N, Chiappini MG, Moscatelli B, Re MA, Pellicciotti L, Benedetti G, et al. Quality of life of COPD patients treated by long-term oxygen. Lung. Suppl. 1990;168:93. No baseline data
27 De Angelis G, Sposato B, Mazzei L, Giocondi F, Sbrocca A, Propati A, et al. Predictive indexes of nocturnal desaturation in COPD patients not treated with long term oxygen therapy. European Review for Medical & Pharmacological Sciences. 2001;5(5–6):173-179. [pmid: 12201668]. not LTOT
28 Domingo C, Roig J, Coll R, Klamburg J, Izquierdo J, RuizManzano J, et al. Evaluation of the use of three different devices for nocturnal oxygen therapy in COPD patients. Respiration. 1996;63(4):230-235. [pmid: 8815970]. No outcome of interest
29 DomingoSalvany A, Lamarca R, Ferrer M, GarciaAymerich J, Alonso J, Felez M, et al. Health-related quality of life and mortality in male patients with chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2002;166(5):680-685. [pmid: 12204865]. Not LTOT
30 Earnest MA. Explaining adherence to supplemental oxygen therapy: the patient's perspective. Journal of General Internal Medicine. 2002;17(10):749-755. [pmid: 12390550]. No baseline data
31 Eaton T, Garrett JE, Young P, Fergusson W, Kolbe J, Rudkin S, et al. Ambulatory oxygen improves quality of life of COPD patients: a randomised controlled study. European Respiratory Journal. 2002;20(2):306-312. [pmid: 12212960]. Not population of interest
32 Eldridge F, Gherman C. Studies of oxygen administration in respiratory failure. Annals of Internal Medicine. 1968;68(3):569-578. [pmid: 5238810]. Not LTOT
33 Elliott MW, Mulvey DA, Moxham J, Green M, Branthwaite MA. Domiciliary nocturnal nasal intermittent positive pressure ventilation in COPD: mechanisms underlying changes in arterial blood gas tensions. European Respiratory Journal. 1991;4(9):1044-1052. [pmid: 1756837]. n< 10
34 Elliott MW. Noninvasive ventilation in COPD patients with chronic respiratory failure--con. Monaldi Archives for Chest Disease. 2000;55(1):58-61. [pmid: 10809564]. Review
35 Estopa RM, Monasterio C, Escarrabill J. Daily life desaturations in COPD patients on LTOT: International Oxygen Club multicentre European study. Monaldi Archives for Chest Disease. 1993;48(5):426-428. [pmid: 8312895]. No outcomes of interest
36 Fairshter RD, Wilson AF. Nonpharmacologic treatment of chronic obstructive pulmonary disease. Comprehensive Therapy. 1982;8(9):35-41. [pmid: 6754240]. Review
37 Faulkner MA, Hilleman DE. The economic impact of chronic obstructive pulmonary disease. Expert Opinion on Pharmacotherapy. 2002;3(3):219-228. [pmid: 11866672]. Review
38 Findley LJ, Whelan DM, Moser KM. Long-term oxygen therapy in COPD. Chest. 1983;83(4):671-674. [pmid: 6403304]. Review
39 Flenley DC, Calverly PM, Douglas NJ, Catterall JR, Lamb D, Brezinova V. Nocturnal hypoxemia and long-term domiciliary oxygen therapy in "blue and bloated" bronchitics. Physiopathologic correlations. Chest. 1980;77(2:Suppl). Suppl-7. No outcomes of interest
40 Fletcher EC, Levin DC. Cardiopulmonary hemodynamics during sleep in subjects with chronic obstructive pulmonary disease. The effect of short- and long-term oxygen. Chest. 1984;85(1):6-14. [pmid: 6690253]. n < 10
41 Fletcher EC, Luckett RA, GoodnightWhite S, Miller CC, Qian W, CostarangosGalarza C. A double-blind trial of nocturnal supplemental oxygen for sleep desaturation in patients with chronic obstructive pulmonary disease and a daytime PaO2 above 60 mm Hg. American Review of Respiratory Disease. 1992;145(5):1070-1076. [pmid: 1586049]. Not population of interest
42 Fletcher EC, Donner CF, Midgren B, Zielinski J, LeviValensi P, Braghiroli A, et al. Survival in COPD patients with a daytime PaO2 greater than 60 mm Hg with and without nocturnal oxyhemoglobin desaturation. Chest. 1992;101(3):649-655. [pmid: 1541127]. Data not stratified by tx / non_tx groups
43 Foucher P, Baudouin N, Merati M, Pitard A, Bonniaud P, ReybetDegat O, et al. Relative survival analysis of 252 patients with COPD receiving long-term oxygen therapy. Chest. 1998;113(6):1580-1587. [pmid: 9631797]. Subset of Chailleux 2003
44 Fujimoto K, Matsuzawa Y, Yamaguchi S, Koizumi T, Kubo K. Benefits of oxygen on exercise performance and pulmonary hemodynamics in patients with COPD with mild hypoxemia. Chest. 2002;122(2):457-463. [pmid: 12171817]. Not LTOT
45 Fussell KM, Ayo DS, Branca P, Rogers JT, Rodriguez M, Light RW. Assessing need for long-term oxygen therapy: a comparison of conventional evaluation and measures of ambulatory oximetry monitoring. Respiratory Care. 2003;48(2):115-119. [pmid: 12556251]. No outcomes of interest
46 Gajanan G. Long term domiciliary oxygen therapy in chronic obstructive pulmonary disease. National Medical Journal of India. 1993;6(5):219-220. [pmid: 8241937]. Report
47 Garrod R, Bestall JC, Paul E, Wedzicha JA. Evaluation of pulsed dose oxygen delivery during exercise in patients with severe chronic obstructive pulmonary disease.[see comment]. Thorax. 1999;54(3):242-244. [pmid: 10325901]. n <10
48 Garrod R, Paul EA, Wedzicha JA. Supplemental oxygen during pulmonary rehabilitation in patients with COPD with exercise hypoxaemia.[see comment]. Thorax. 2000;55(7):539-543. [pmid: 10856310]. Not LTOT
49 Garrod R, Mikelsons C, Paul EA, Wedzicha JA. Randomized controlled trial of domiciliary noninvasive positive pressure ventilation and physical training in severe chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2000;162(4:Pt 1):t-41. Mean PaO2 > 65 & no LTOT
50 Gibbons D, Conneelly J, Smith J. An audit of provision of long-term oxygen therapy for COPD patients. Professional Nurse. 2002;18(2):107-110. Report/audit
51 Hanson CW III, Marshall BE, Frasch HF, Marshall C. Causes of hypercarbia with oxygen therapy in patients with chronic obstructive pulmonary disease. Critical Care Medicine. 1996;24(1):23-28. [pmid: 8565533]. Study of computer model with use of pt data
52 Hjalmarsen A, Aasebo U, Aleksandersen G, Jorde R. Cardiovascular responses to tests for autonomic dysfunction in patients with chronic obstructive pulmonary disease with and without continuous long-term oxygen therapy. Journal of the Autonomic Nervous System. 1996;60(3):169-174. [pmid: 8912267]. No outcomes of interest, N<10
53 Hoang Thi TH, Guillemin F, Cornette A, Polu JM, Briancon S. Health-related quality of life in long-term oxygen-treated chronic obstructive pulmonary disease patients. Lung. 1997;175(1):63-71. [pmid: 8959674]. No outcomes of interest
54 Hoffman LA, Dauber JH, Ferson PF, Openbrier DR, Zullo TG. Patient response to transtracheal oxygen delivery. American Review of Respiratory Disease. 1987;135(1):153-156. [pmid: 3800142]. Evaluation of transtrachial oxygen
55 Hoffman LA, Johnson JT, Wesmiller SW, Sciurba FC, Ferson PF, Mazzocco MC, et al. Transtracheal delivery of oxygen: efficacy and safety for long-term continuous therapy. Annals of Otology, Rhinology & Laryngology. 1991;100(2):108-115. Evaluation of TT method
56 Hoffman LA, Wesmiller SW, Sciurba FC, Johnson JT, Ferson PF, Zullo TG, et al. Nasal cannula and transtracheal oxygen delivery. A comparison of patient response after 6 months of each technique. American Review of Respiratory Disease. 1992;145(4:Pt 1):t-31. No baseline data
57 Ibanez M, Aguilar JJ, Maderal MA, Prats E, Farrero E, Font A, et al. Sexuality in chronic respiratory failure: coincidences and divergences between patient and primary caregiver. Respiratory Medicine. 2001;95(12):975-979. [pmid: 11778795]. No baseline data
58 Jakobsson P, Jorfeldt L. Long-term oxygen therapy may improve skeletal muscle metabolism in advanced chronic obstructive pulmonary disease patients with chronic hypoxaemia. Respiratory Medicine. 1995;89(7):471-476. [pmid: 7480976]. n < 10
59 Jones SE, Packham S, Hebden M, Smith AP. Domiciliary nocturnal intermittent positive pressure ventilation in patients with respiratory failure due to severe COPD: long-term follow up and effect on survival.[see comment]. Thorax. 1998;53(6):495-498. [pmid: 9713450]. Not LTOT
60 Kampelmacher MJ, van Kestern RG, Alsbach GP, Melissant CF, Wynne HJ, Douze JM, et al. Characteristics and complaints of patients prescribed long-term oxygen therapy in The Netherlands. Respiratory Medicine. 1998;92(1):70-75. [pmid: 9519228]. Not population of interest
61 Kampelmacher MJ, Van Kesteren RG, Alsbach GP, Melissant CF, Wynne HJ, Douze JM, et al. Prescription and usage of long-term oxygen therapy in patients with chronic obstructive pulmonary disease in The Netherlands. Respiratory Medicine. 1999;93(1):46-51. [pmid: 10464848]. No baseline data
62 Kampelmacher MJ, van Kestern RG, Alsbach GP, Melissant CF, Wynne HJ, Douze JM, et al. Characteristics and complaints of patients prescribed long-term oxygen therapy in The Netherlands. Respir Med. 1998;92:70-75. [pmid: 9519228]. No outcomes of interest
63 Katsura H, Ogata M, Kida K. Factors determining outcome in elderly patients with severe COPD on long-term domiciliary oxygen therapy. Monaldi Archives for Chest Disease. 2001;56(3):195-201. [pmid: 11665497]. Not population of interest
64 Lareau S. The effect of positive-pressure breathing on the arterial oxygen tension in patients with chronic obstructive pulmonary disease receiving oxygen therapy. Heart & Lung: Journal of Acute & Critical Care. 1976;5(3):449-452. Not LTOT
65 Lefcoe N, Carter P. Intermittent positive-pressure breathing in chronic obstructive pulmonary disease. Canadian Medical Association Journal. 1970;103(3):279-281. [pmid: 4914982]. Not LTOT
66 LeviValensi P, Weitzenblum E, Pedinielli JL, Racineux JL, Duwoos H. Three-month follow-up of arterial blood gas determinations in candidates for long-term oxygen therapy. A multicentric study. American Review of Respiratory Disease. 1986;133(4):547-551. [pmid: 3083740]. No outcomes of interest
67 LeviValensi P, Jounieaux V, Aubry P, Rose D, Aouine H, Rida Z. Sleep disorders and oxygen therapy in chronic bronchitis-emphysema. European Respiratory Journal - Supplement. 1990;11:519s-522s. Not LTOT
68 LeviValensi P, Weitzenblum E, Rida Z, Aubry P, Braghiroli A, Donner C, et al. Sleep-related oxygen desaturation and daytime pulmonary haemodynamics in COPD patients.[erratum appears in Eur Respir J 1992 May;5(5):645]. European Respiratory Journal. 1992;5(3):301-307. [pmid: 1572442]. Not LTOT
69 LeviValensi P, Aubry P, Rida Z. Nocturnal hypoxemia and long-term oxygen therapy in COPD patients with daytime PaO2 60–70 mmHg. Lung. 1990;168. Suppl-5. Protocol only, no data
70 Little SA, Elkholy MM, Chalmers GW, Farouk A, Patel KR, Thomson NC. Predictors of nocturnal oxygen desaturation in patients with COPD. Respiratory Medicine. 1999;93(3):202-207. [pmid: 10464879]. Not LTOT
71 MacNee W. Predictors of survival in patients treated with long-term oxygen therapy. Respiration. 1992;59. Suppl-7. Commentary/review
72 Malik SK. Oxygen therapy in chronic obstructive pulmonary disease. Indian J Chest Dis. 1969;11:186-195. [pmid: 5398324]. No outcomes of interest
73 McDermott SC. Use of a wheelchair oxygen walker in exercise and rehabilitation of patients with chronic obstructive pulmonary disease. Respiratory Care. 1977;22(11):1222-1225. [pmid: 10314832]. Not LTOT
74 McDonald CF, Blyth CM, Lazarus MD, Marschner I, Barter CE. Exertional oxygen of limited benefit in patients with chronic obstructive pulmonary disease and mild hypoxemia. American Journal of Respiratory & Critical Care Medicine. 1995;152(5:Pt 1):t-9. Not population of interest
75 Meecham Jones DJ, Paul EA, Jones PW, Wedzicha JA. Nasal pressure support ventilation plus oxygen compared with oxygen therapy alone in hypercapnic COPD. American Journal of Respiratory & Critical Care Medicine. 1995;152(2):538-544. [pmid: 7633704]. Primary to evaluate nPPV, pts had LTOT at baseline
76 Montner P, Sergent M, Case E, Douglas M, Griego E, Martinez F, et al. TQI in the Albuquerque Veterans Affairs Medical Center's long-term oxygen therapy program. Joint Commission Journal on Quality Improvement. 1998;24(4):203-211. [pmid: 9589333]. Not LTOT
77 Morrison D, Skwarski K, MacNee W. Review of the prescription of domiciliary long term oxygen therapy in Scotland.[erratum appears in Thorax 1995 Dec;50(12):1327]. Thorax. 1995;50(10):1103-1105. [pmid: 7491562]. No outcomes of interest
78 Morrison D, Skwarski KM, MacNee W. The adequacy of oxygenation in patients with hypoxic chronic obstructive pulmonary disease treated with long-term domiciliary oxygen.[erratum appears in Respir Med 1997 Aug;91(7):442]. Respiratory Medicine. 1997;91(5):287-291. [pmid: 9176647]. No outcomes of interest
79 Murata GH, Gorby MS, Kapsner CO, Chick TW, Halperin AK. A multivariate model for the prediction of relapse after outpatient treatment of decompensated chronic obstructive pulmonary disease. Archives of Internal Medicine. 1992;152(1):73-77. [pmid: 1728932]. Not LTOT
80 O'Donohue WJ Jr. Effect of oxygen therapy on increasing arterial oxygen tension in hypoxemic patients with stable chronic obstructive pulmonary disease while breathing ambient air. Chest. 1991;100(4):968-972. [pmid: 1914613]. No outcomes of interest
81 Oba Y, Salzman GA, Willsie SK. Reevaluation of continuous oxygen therapy after initial prescription in patients with chronic obstructive pulmonary disease.[see comment]. Respiratory Care. 2000;45(4):401-406. [pmid: 10780035]. No outcomes of interest
82 Okubadejo AA, Paul EA, Wedzicha JA. Domiciliary oxygen cylinders: indications, prescription and usage. Respiratory Medicine. 1994;88(10):777-785. [pmid: 7846340]. No LTOT
83 Okubadejo AA, O'Shea L, Jones PW, Wedzicha JA. Home assessment of activities of daily living in patients with severe chronic obstructive pulmonary disease on long-term oxygen therapy. European Respiratory Journal. 1997;10(7):1572-1575. [pmid: 9230249]. No baseline, enrollment criteria includes pts already on LTOT
84 PelletierFleury N, Lanoe JL, Fleury B, Fardeau M. The cost of treating COPD patients with long-term oxygen therapy in a French population. Chest. 1996;110(2):411-416. [pmid: 8697843]. Cost analysis
85 Pepin JL, Barjhoux CE, Deschaux C, Brambilla C. Long-term oxygen therapy at home. Compliance with medical prescription and effective use of therapy. ANTADIR Working Group on Oxygen Therapy. Association Nationale de Traitement a Domicile des Insuffisants Respiratories.[see comment]. Chest. 1996;109(5):1144-1150. [pmid: 8625658]. No outcomes of interest
86 Perrin C, El Far Y, Vandenbos F, Tamisier R, Dumon MC, Lemoigne F, et al. Domiciliary nasal intermittent positive pressure ventilation in severe COPD: effects on lung function and quality of life. European Respiratory Journal. 1997;10(12):2835-2839. [pmid: 9493670]. Combined NIPPV & LTOT, no comparison group
87 Pilling J, Cutaia M. Ambulatory oximetry monitoring in patients with severe COPD: a preliminary study. Chest. 1999;116(2):314-321. [pmid: 10453857]. Not LTOT
88 Plywaczewski R, Sliwinski P, Nowinski A, Kaminski D, Zielinski J. Incidence of nocturnal desaturation while breathing oxygen in COPD patients undergoing long-term oxygen therapy.[see comment]. Chest. 2000;117(3):679-683. [pmid: 10712991]. No outcomes of interest
89 Revill SM, Singh SJ, Morgan MD. Randomized controlled trial of ambulatory oxygen and an ambulatory ventilator on endurance exercise in COPD. Respiratory Medicine. 2000;94(8):778-783. [pmid: 10955754]. Not LTOT
90 Ringbaek TJ, Lange P, Viskum K. Are patients on long-term oxygen therapy followed up properly? Data from the Danish Oxygen Register. Journal of Internal Medicine. 2001;250(2):131-136. [pmid: 11489062]. No outcomes of interest
91 Ringbaek TJ, Viskum K, Lange P. Non-continuous home oxygen therapy: utilization, symptomatic effect and prognosis, data from a national register on home oxygen therapy. Respiratory Medicine. 2001;95(12):980-985. [pmid: 11778796]. No PaO2, part of Danish Registry (Ringbeck 2002)
92 Roberts CM, Bell J, Wedzicha JA. Comparison of the efficacy of a demand oxygen delivery system with continuous low flow oxygen in subjects with stable COPD and severe oxygen desaturation on walking. Thorax. 1996;51(8):831-834. [pmid: 8795673]. Not LTOT, comparison of delivery systems
93 Rooyackers JM, Dekhuijzen PN, Van Herwaarden CL, Folgering HT. Training with supplemental oxygen in patients with COPD and hypoxaemia at peak exercise. European Respiratory Journal. 1997;10(6):1278-1284. [pmid: 9192929]. Not LTOT
94 Roselle S, D'Amico FJ. The effect of home respiratory therapy on hospital readmission rates of patients with chronic obstructive pulmonary disease. Respiratory Care. 1982;27(10):1194-1199. [pmid: 10315311]. Not LTOT
95 Rudkin S. Home support for patients on long-term oxygen therapy. Nursing Times. 1996;92(34):34-35. [pmid: 8850723]. Not LTOT
96 Sampablo I, Escarrabill J, Rosell A, Manresa F, Estopa R. Transtracheal catheter acceptance and adverse events in long-term home oxygen therapy. Monaldi Archives for Chest Disease. 1998;53(2):123-126. [pmid: 9689795]. AE of TT per se, not LTOT
97 Sant'Anna CA, Stelmach R, Zanetti Feltrin MI, Filho WJ, Chiba T, Cukier A. Evaluation of health-related quality of life in low-income patients with COPD receiving long-term oxygen therapy. Chest. 2003;123(1):136-141. [pmid: 12527614]. No baseline data
98 Schonhofer B, Barchfeld T, Wenzel M, Kohler D. Long term effects of non-invasive mechanical ventilation on pulmonary haemodynamics in patients with chronic respiratory failure. Thorax. 2001;56(7):524-528. [pmid: 11413350]. Not LTOT
99 Shankar P, Muthiah MM. Audit on prescription of long-term oxygen treatment. Clinical Performance & Quality Health Care. 2000;8(3):134-135. [pmid: 11185827]. Report/audit
100 Silverman BG, Gross TP, Babish JD. Home oxygen therapy in Medicare beneficiaries, 1991 and 1992. Chest. 1997;112(2):380-386. [pmid: 9266872]. No outcomes of interest
101 Sivakumaran P, Garrett JE. The prescription of domicilary long-term oxygen therapy in Auckland.[see comment]. New Zealand Medical Journal. 1996;109(1034):439-442. [pmid: 8982174]. No outcomes of interest
102 Sliwinski P, Lagosz M, Gorecka D, Zielinski J. The adequacy of oxygenation in COPD patients undergoing long-term oxygen therapy assessed by pulse oximetry at home. European Respiratory Journal. 1994;7(2):274-278. [pmid: 8162980]. No outcomes of interest
103 Soffer M, Tashkin DP, Shapiro BJ, Littner M, Harvey E, Farr S. Conservation of oxygen supply using a reservoir nasal cannula in hypoxemic patients at rest and during exercise. Chest. 1985;88(5):663-668. [pmid: 3931988]. No outcomes of interest
104 Strom K, Boe J. A national register for long-term oxygen therapy in chronic hypoxia: preliminary results. European Respiratory Journal. 1988;1(10):952-958. [pmid: 3224692]. No outcomes of interest
105 Strumpf DA, Millman RP, Carlisle CC, Grattan LM, Ryan SM, Erickson AD, et al. Nocturnal positive-pressure ventilation via nasal mask in patients with severe chronic obstructive pulmonary disease. American Review of Respiratory Disease. 1991;144(6):1234-1239. [pmid: 1741532]. Comparison of NNV vs standard care, not all pts on supplemental oxygen
106 Tiep BL, Nicotra B, Carter R, Belman MJ, Mittman C. Evaluation of a low-flow oxygen-conserving nasal cannula. American Review of Respiratory Disease. 1984;130(3):500-502. [pmid: 6476597]. Not LTOT, comparison of oxygen delivery system
107 Tiep BL, Barnett J, Schiffman G, Sanchez O, Carter R. Maintaining oxygenation via demand oxygen delivery during rest and exercise. Respiratory Care. 2002;47(8):887-892. [pmid: 12162799]. Not LTOT
108 Tzanakis N, Bouros D, Mamatzakis P, Samiou M, Siafakas NM. Long-term oxygen therapy on the island of Crete, Greece. Monaldi Archives for Chest Disease. 1998;53(5):533-536. [pmid: 9861814]. Not outcomes study
109 Veale D, Chailleux E, Taytard A, Cardinaud JP. Characteristics and survival of patients prescribed long-term oxygen therapy outside prescription guidelines.[see comment]. European Respiratory Journal. 1998;12(4):780-784. [pmid: 9817145]. Duplicate paper, see Chailleux
110 Vergeret J, Tunon DL, Douvier JJ, Freour P, Cardinaud JP, Courty G, et al. Compliance of COPD patients with long term oxygen therapy. European Journal of Respiratory Diseases - Supplement. 1986;146:421-425. [pmid: 3096758]. No outcomes of interest
111 Wedzicha JA. Domiciliary oxygen therapy services: clinical guidelines and advice for prescribers. Summary of a report of the Royal College of Physicians. Journal of the Royal College of Physicians of London. 1999;33(5):445-447. [pmid: 10624659]. Review
112 Weitzenblum E, Apprill M, Oswald M. Benefit from long-term O2 therapy in chronic obstructive pulmonary disease patients. Respiration. 1992;59. Suppl-7. Review/report
113 Wijkstra PJ, Guyatt GH, Ambrosino N, Celli BR, Guell R, Muir JF, et al. International approaches to the prescription of long-term oxygen therapy.[see comment]. European Respiratory Journal. 2001;18(6):909-913. [pmid: 11829095]. Report
114 Wright RW, Larsen DF, Monie RG, Aldred RA. Benefits of a community-hospital pulmonary rehabilitation program. Respiratory Care. 1983;28(11):1474-1479. [pmid: 10315481]. Not LTOT
115 Wurtemberger G, Hutter BO. Health-related quality of life, psychological adjustment and compliance to treatment in patients on domiciliary liquid oxygen. Monaldi Archives for Chest Disease. 2000;55(3):216-224. [pmid: 10948670]. No baseline data
116 Young IH, Crockett AJ, McDonald CF. Adult domiciliary oxygen therapy. Position statement of the Thoracic Society of Australia and New Zealand. Medical Journal of Australia. 1998;168(1):21-25. [pmid: 9451391]. Review
117 Zack MB, Palange AV, Drews PG, Stehm D. Ventilatory and nonventilatory muscle exercise in COPD rehabilitation. Respiratory Therapy. 1984;14(5). 41-45N. LTOT
118 Zeng GB, Zhang ZX, Xu YJ, Duan SF. Effects of exercise on pulmonary gas exchange and oxygen transport in chronic obstructive pulmonary diseases. Chinese Medical Journal. 1992;105(1):49-54. [pmid: 1576870]. Not LTOT
119 Zielinski J. Indications for long-term oxygen therapy: a reappraisal. Monaldi Archives for Chest Disease. 1999;54(2):178-182. [pmid: 10394836]. Review
120 Zinman C, Richards GA, Taylor R, Mer M. Long-term domiciliary oxygen therapy--the Johannesburg Hospital experience. South African Medical Journal. 2000;90(6):617-621. [pmid: 10918893]. No outcome of interest