# Evidence Tables

Evidence Table 1 Randomized controlled trials of LTOT for COPD patients with PaO_2_ ≤55 mmHg

Study Year Country | Study design | | Population | Baseline | | O_2_ therapy hrs/day | Outcomes | | Comments
Study Year Country | Duration; RCT features | Inclusion / exclusion | Population | PaO_2_ PaCO_2_ mmHg | FEV_1_ (% Predicted) | O_2_ therapy hrs/day | Mortality | Other outcomes | Comments
Fleetham 1980 Canada | 1 y F/U | Inclusion: FEV_1_/VC < 70%, and if TLC ≥80% P nl, PaO_2_<56 or <59 mmHg w/ankle edema > 3 wk of infection-free clinical stability on intensive bronchodilator | N=16 Male: ND Age: ND | PaO_2_ 52±0.7 PaCO_2_ 46±1.2 | 25±2.9 SE | COT 24 | ND | Pulmonary function at 6m FEV_1_% 25±2.9 (SE) NS n=11 | Oxygen compliance monitored by nurses, no patients lost to F/U
Fleetham 1980 Canada | 1 y F/U | Inclusion: FEV_1_/VC < 70%, and if TLC ≥80% P nl, PaO_2_<56 or <59 mmHg w/ankle edema > 3 wk of infection-free clinical stability on intensive bronchodilator | N=14 Male: ND Age: ND | PaO_2_ 52±1.3 PaCO_2_ 44±1.5 SE | 22±2.3 SE | NOT 12 | ND | FEV_1_% 21±3.3 (SE) NS n=12 | Oxygen compliance monitored by nurses, no patients lost to F/U
NOTT 1980 Heaton 1983 US | 19.3 mo average F/U; Block randomization within each 6 sites | Inclusion: >35 y, clinical diagnosis of COPD, PaO_2_ ≤ 55 mmHg or PaCO_2_ ≤ 59 plus edema, hematocrit ≥ 55%, P pulmonale on ECG, FEV_1_/FVC <70%, TLC ≥ 80% predicted Exclusion: previous O_2_ 12h/d for 30 d prior 2 m, other disease that might influence outcomes | Total N=203 COT n=101 NOT n=102 Male: 79% Age: 65 | COT PaO_2_ 51 PaCO_2_ 43 | COT 30 | COT 18±4.8 | 12 mo COT 12%±3.2 (SE) NOT 21%±4.0 (SE) odds ratio 0.53 (0.25–1.11) 24 mo COT 22%± 4.6 (SE) NOT 41%±5.5 (SE) odds ratio 0.45 (0.25–0.81) | Hematocrit decrease at 18 mo; Pulmonary vascular resistance at 6 mo; Neuropsychological evaluation at 6 mo (n=150) Small improvements noted in most measures but formal statistical test were not presented for two treatment groups. HQOL NS for either groups on QOL measures Hospitalization COT decrease trend for number of admissions and LOS compared to NOT but NS. | 2 COT patients lost to F/U
  NOT (n=36) | 2.0%
  COT (n=40) | 9.2% | p=0.008
  NOT (n=49) | +6.5%
  COT (n=52) | −11% | p=0.04
NOTT 1980 Heaton 1983 US | 19.3 mo average F/U; Block randomization within each 6 sites | | Total N=203 COT n=101 NOT n=102 Male: 79% Age: 65 | NOT PaO_2_ 52 PaCO_2_ 44 | NOT 30 | NOT 12±2.5 | 12 mo COT 12%±3.2 (SE) NOT 21%±4.0 (SE) odds ratio 0.53 (0.25–1.11) 24 mo COT 22%± 4.6 (SE) NOT 41%±5.5 (SE) odds ratio 0.45 (0.25–0.81) | | 2 COT patients lost to F/U
MRC Stuart-Harris 1981 UK | 5 y F/U; table of random numbers, unblinded | Inclusion: <70, chronic bronchitis or emphysema with FEV_1_ <1.2L, PaO_2_ 40– 60 mmHg Exclusion: fibrotic or infiltrative lung disorder, pneumonconiosis, severe kyphoscoliosis, pulmonary embolism, elevated BP, coronary arterial or other life-threatening disease | N=87 Treatment: 42 Control: 45 Male: 76% Age: 58 (42–69) | PaO_2_ 51 PaCO_2_ 54 | FEV_1_ L ~0.6 W ~0.7 M | >15 | 5 years Treatment: 45% Control: 67% OR 0.42 (0.18, 0.98) | “There are no significant different between the groups in physiological variables, hospital stay and work record.” | 3 centers 1 withdrawal from treatment group
Cuvelier 2002 France | ND; Cross-over, double dummy, single-blind | Inclusion: stable COPD, LTOT at home, able to perform walking tests | N=10 Male: 90% Age: 65 | PaO_2_ 55± 6.3 PaCO_2_ 46± 7.4 | 98± 27 | ND | ND | Mean walking distance test Room air 334.5±90m (A) O_2_ 374±81 m p=0.03 (B) O_2_ 375±97 m p=0.02 | ---

Mean and standard deviation unless otherwise noted.

Abbreviations: COT, continuous oxygen therapy; d, day(s); F/U, follow-up; LOS, length of stay; m, month(s); ND, no data; NOT, nocturnal oxygen therapy; OR, odds ratio; PAP, pulmonary artery pressure; SE, standard error; y, year.

Evidence Table 2 Randomized controlled trials of LTOT for COPD patients with PaO_2_ 60–64 mmHg

Study Year Country | Study design | | Population | Baseline | | O_2_ therapy hours/day | Outcomes | | Comments
Study Year Country | Duration / RCT features | Inclusion / exclusion | Population | PaO_2_ PaCO_2_ mmHg | FEV_1_ % Predicted | O_2_ therapy hours/day | Mortality | Other outcomes | Comments
Gorecka 1997 Poland | 7 y F/U, mean 41 mo; Computer central generated random numbers, not blinded | Inclusion: single diagnosis COPD, 40–80 y with airway limitation (FEV_1_/VC post bronchodilator of <70%, PaO_2_ 56–65 from 1987–92, F/U through 1994 Exclusion: serious disease of organs other than lungs that might influence survival | N=135 Male: 76% Age: 61 | PaO_2_ 60±2.8 PaCO_2_ 44±6.7 | 30±9.8 | 14 | LTOT 56% Control 49% Odds Ratio (all-cause) 1.4 (0.70–2.7) | | 9 regional LTOT centers, no patients lost to F/U
Chaouat 1999 Europe | 35 mo F/U Table of random sampling numbers, NOT to even numbers, control to odd numbers, unblinded | Inclusion: FEV_1_/VC ratio <60% predicted value, 2 PaO_2_ measures 56–69 (4 weeks apart), PaCO_2_ ≥45, nocturnal desaturation ≥ 30% & SaO_2_ < 90% Exclusion: left or congenital heart, or interstitial lung diseases, bronchiectasis, disease that might affect outcomes, sleep apnea | N=76 Male: ND Age: 63 NOT: 41 No NOT control: 35 | PaO_2_ 63±3.3 PaCO_2_ 45±5.6 | 39±16 | NOT 8.9±1.9 | NOT 22% Control 20% Odds Ratio 1.1 (0.37–3.4) | There was no significant change in pulmonary volumes, FEV_1_ and resting and exercising PAP | 12 NOT & 10 controls received LTOT due to fall in PaO_2_ levels, mortality analyses on intention to treat, similar results if LTOT exposure removed, 6 outpatient centers, 11 withdrawals, 2 lost to F/U

Evidence Table 3 Cohort studies of LTOT for COPD patients with PaO_2_ ≤55 mmHg

Study Year Country | Study design | | Population | Baseline | | O_2_ therapy: hours/day | Outcomes | | Comments
Study Year Country | Duration | Inclusion / exclusion | Population | PaO_2_ PaCO_2_ mmHg | FEV_1_ (% Predicted) | O_2_ therapy: hours/day | Mortality | Other outcomes | Comments
Prospective
Krop 1973 Stewart 1975 US | 25.2 mo F/U (4 – 40) | Inclusion: COPD, PaO_2_ < 55 mmHg under optimal therapy, additional PaO_2_ decrease with treadmill exercise, relief of hypoxemia with 2 L/min O_2_ therapy | N=12 Male: 100% Age: 55 (33–64) | PaO_2_ 49±5.0 PaCO_2_ 44±6.9 | FEV_1_ L 0.68±0.15 | 24 | 1y 8.3% 2y 33% (graph estimates) | Survival 56% at 2½ y Pulmonary function (n=11) NS for PaCO_2_, FVC, FEV_1_ Hospital days ~30 days/patient before LTOT (n=11) ~20 days/patient 1 year after LTOT (n=10) Quality of life at 1 month | VA patients, no patient lost to F/U
  | ___ | [underlined: Post]
  WAIS or W-B
  FSIQ | 97.0 | 103.1 | p<.05
  VIQ | 99.0 | 103.3 | NS
  PIQ | 93.6 | 102.0 | p<.01
  WMS | 97.8 | 105.6 | p<.01
  B-G | 23.0 | 9.2 | p<.01
  BIP | 24.8 | 9.9 | p<.005
  FRT | 7.4 | 7.5 | NS
  FT(T) | 29.4 | 41.8 | p<.005
  MMPI
  Depression | 24.9 | 18.4 | p<.05
  Hypochondriasis | 20.7 | 14.2 | p<.005
  Hysteria | 24.8 | 17.4 | p<.025
  Social introversion | 27.5 | 20.0 | p<.05
  Diaries - all report ADL improvement
Ashutosh 1983 USA | 2 y F/U | Inclusion: FEV_1_ < 2 SD predicted value and FEV_1_/FVC% < 70%, right heart failure, mean PAP > 20 mmHg, pulmonary capillary wedge pressure < 15 mmHg Exclusion: left ventricular disease | Responders PAP: 37±12 N=17 Male: ND Age: 57 | PaO_2_ 53±8 PaCO_2_ 46±9 | FEV_1_ L 0.94±0.51 | Prescribed > 18 | 2 y 13% | Survival Significant for responders (reduction in pulmonary hypertension) over non-responders, p<0.005 | Significant change of PAP > or < 5 mmHg while breathing 28% O_2_ for 24 h used to divide patients into 2 groups; 1 withdrawal
Ashutosh 1983 USA | 2 y F/U | Inclusion: FEV_1_ < 2 SD predicted value and FEV_1_/FVC% < 70%, right heart failure, mean PAP > 20 mmHg, pulmonary capillary wedge pressure < 15 mmHg Exclusion: left ventricular disease | Non-responders PAP: 33±12 N=11 Male: ND Age: 60 | PaO_2_ 54±12 PaCO_2_ 46±10 | FEV_1_ L 0.83±0.58 | Prescribed > 18 | 2 y 78% | Survival Significant for responders (reduction in pulmonary hypertension) over non-responders, p<0.005 | 2 withdrawals
Weitzenblum 1985 1991 France | 11.5 y F/U, 44±30 mo of therapy (12–120) | Inclusion: history of chronic bronchitis, air-flow obstruction < 1.5 L, hypoxemia & PaO_2_ < 60 mmHg & clinically stable at 3 monthlymeasures, right heart failure or right ventricular hypertrophy, Ppa>20 mmHg, ≥ 1 y between catheterization before & after onset of LTOT, compliance (>15 h/d) Exclusion: left heart disease, systemic hypertension, chronic pulmonary or severe disease | N=24 Male: 92% Age: 59 (41–74) | PaO_2_ 52±6.5 PaCO_2_ 49±8.2 | 34±14 | 18 | 33 mo 25%* 73 mo 54% *Denominator= 16 | Hospital days per year (n=16) Pre-LTOT 18±16 Post-LTOT 9±19 0.10 > p > 0.05 (NS) Pulmonary function FEV_1_ % 33±13 NS (compared with baseline) Pulmonary arterial hypertension Pre-LTOT 27±9.1 Post-LTOT 24±7.1 ns (compared to baseline) | Ambidirectional study, recruitment & consent given between 2^nd^ and 3^rd^ catheterization, no data on number of pts from onset of LTOT for mortality or dropouts before study enrollment
Vergeret 1989 Denmark | 1 y F/U | Inclusion: 40–75 y, severe COPD FEV_1_/FVC<60%, total lung capacity >80% of reference values, FEV_1_<1L & stable chronic respiratory insufficiency PaO_2_ <8kPa & >5.3kPa PaCO_2_ <8.2kPa Exclusion: pts on portable O_2_, > 3 admissions | Fixed O_2_ N=75 Male: 84% Age: 63 | PaO_2_ 54±7.5 PaCO_2_ ND | FEV_1_ L 0.8±7.4 | 14 | 1 y 12% | No significant clinical and functional differences between 2 groups. | 8 withdrawals
Vergeret 1989 Denmark | 1 y F/U | | Portable O_2_ N=84 Male: 90% Age: 61 | PaO_2_ 54±7.5 PaCO_2_ ND | FEV_1_ L 0.8±7.4 | 17 | 1 y 18% | No significant clinical and functional differences between 2 groups. | 5 withdrawals
Lahdensuo 1989 Finland | 6 mo F/U | Inclusion: severe COPD, stable disease, PaO_2_<55 or 55–59 & hematocrit > 55, cor pulmonale, or history of ≥1 acute cardiac failure from cor pulmonale Exclusion: smoking in the past 3 mo | N=26 Male: 73% Age: 63 | PaO_2_ 49±6.7 PaCO_2_ 46±14 | ND | Prescribed 24 | ND | Psychosocial response BDI 18.2 vs 15.1 p<0.06 No significant changes were observed in any psychosocial measures including depression, general activity & independence, coping skills | ---
Dubois 1990 1994 Belgium | 6 y | Inclusion: PaO_2_ <55 in controlled steady state ≥3 wks, PaCO_2_ did not increase “excessively” Exclusion: A severe disease that might be expected to influences short-term mortality. No patients has had previous LTOT | N=270 Male: 86% Age: 66 | PaO_2_ 48±6 PaCO_2_ 47±9 | 30±12 | 18 | 1 y 30% 2 y 50% 3 y 57% 5 y 83%* 6 y 83%* *(graph estimates) | | ---
Strom 1991 1993 1998 Sweden | 28 mo F/U (15–45) | Inclusion: Stable adults treated for chronic hypoxemia w/LTOT, approx 7.5 kPa, resting > 8 kPa, registered 1/1/87 – 6/30/89 | N=405 Male: 50% Age: 67 | PaO_2_ 50 PaCO_2_ 49 | 27±15 | 18 | 1 y 23% 2 y 44% 3 y 62% Severity subgroup (WHO score) | Hospitalizations (no pre-post data) 44 days/year Annual admissions M 2.8±3.2 F 3.1±3.0 Psychological impact Negative impact on patient or patient/family caused by oxygen therapy, more common with gas cylinder or therapy > 16 h/d | Registry with no exclusion criteria for adults on LTOT, 60 withdrawals
  | [underlined: 1 y] | [underlined: 2 y]
  S0 | 2% | 32%
  S1 | 15% | 30%
  S2 | 24% | 51%
  S3–4 | 52% | 81%
  (graph estimates)
Gorecka 1992 Poland | 1 y F/U | Inclusion: PaO_2_ ≤55 or 56–65 if one of following is present: Hct ≥55%, radiological signs of pulmonary arterial hypertension, ECG signs of right ventricular hypertrophy | N=315 Male: 74% Age: 62 | PaO_2_ 51± 8 PaCO_2_ 51±11 | FEV_1_ L 0.79 ±0.31 | >17 | 1 y 21% | | 12 regional centers, no patients lost to F/U
Dallari 1994 Italy | 24 mo F/U (2–50) | Inclusion: COPD on LTOT from 1987–1992 | N=166 Male: ND Age: 69 | PaO_2_ 54±5.8 PaCO_2_ 51±7.6 | 36±11.3 | 16–20 | 2 y 22% 3 y 33% | Predictors Multivariate stepwise regression analysis showed that RVSP, age, and FEV_1_ were statistically significant independent predictors of survival. | ---
Simonds 1995 England | 1.6 y median for NIPPV (0.1–6.3) 5 y F/U | Inclusion: symptomatic, chronic hypercapnic respiratory failure unresponsive to O_2_ therapy, progressive deterioration in symptoms & arterial blood gas tensions | N=180 33 COPD Male: ND Age*: 57 *Subgroup data | PaO_2_ 46±6.0 PaCO_2_ 62±14 | FEV_1_ L 0.58±0.3 | 7.88 Random subset of 16 which included other respiratory disorders, 48% COPD used supplemental O_2_ therapy | 1 y 15% 2 y 24% 3 y 32% 4 y 55% 5 y 55% (graph estimates) | Pulmonary function (n=30 COPD) NS for FEV_1_ Sleep quality* Very good 21% Average 67% Poor 5% Adverse events* Inconvenience (20) Nasal/mask problems (10) Gastric distension (3) Noise (3) *no baseline data, includes all diagnoses | Pts may have transitioned from other O_2_ therapy; NIPPV therapy started in hospital, 5 withdrawals
Oswald-mannosser 1995 France | 5 y (1–12 F/U) | Inclusion: COPD, FEV_1_/VC ratio < 60%, TLC > 80% of predicted value Exclusion: Lung disease, (sequelae of pulmonary tuberculosis, pneumoconiosis), left health disease, obesity (BMI > 32), sleep apnea, or other severe disease | N=84 Male: 89% Age: 63 | PaO_2_ 52±5.4 PaCO_2_ 45±7.6 | FEV_1_ L 0.8 (0.3) | >16 | 3 y 29% 5 y 52% | Survival rate PAP <25 mmHg vs. PAP>=25 mmHg p<0.001 The level of PAP (together with age) is a good indicator of survival in COPD patients receiving LTOT | ---
Borak 1996 Poland | 1 y F/U | Inclusion: PaO_2_ < 55 mmHg, or 55–65 if polycythemic | N=124 Male 68% Age: 56 (28–76) | PaO_2_ 55±6.2 PaCO_2_ 47±8.2 | FEV_1_ L 0.88±0.44 | 15 | 27% | Psychological impact (n=90) Significant improvement, p<0.001, for: Bourdon-Wiersma Test – correct deletion Rey test remembered words Depression Anxiety Psychological tension General mood Self-esteem Attitude towards therapy, future & life goals Tests include VRT, MAS, Beck’s Depression Scale, SOPER) | All baseline data for survivors only n=90, no patients lost to F/U
Lin 1996 Taiwan | 2 weeks of therapy | Inclusion: stable hypercapnia, PaO_2_≥ 44 mmHg, FEV_1_P<70%, FEV_1_/FVC <70%, FEV_1_/FVC < 50% predicted, PaO_2_ < 55 mmHg, or PaO_2_ >55–60 right heart failure & polycythemia Exclusion: sleep apnea with hypopnea index ≥10, >15% increase in FEV_1_, CNS, neuromuscular, CHF, endocrine, renal, or unstable disorders < 1 mo | N=12 Male: 58% Age: 65 | PaO_2_ 52±2.5 PaCO_2_ 51±3.5 | ND | 24 | | Sleep stages/efficiency* NS for the following (compared to baseline): Sleep efficiency Sleep latency Arousal index Movement index Snore index Total sleep time Stage 1 through 4 REM *All therapy in hospital | No patients lost to F/U
Clini 1996 Italy | 18 mo of therapy | Inclusion: COPD on LTOT ≥ 18 months, chronic hypercapnia, PaCO_2_> 50, ≥ one hospital admission due to severe exacerbation in past 18 months Exclusion: ≥ 15% increase FEV_1_ | LTOT N=17 Male: 53% Age: 67 | PaO_2_ 50± 4.5 PaCO_2_ 48 ± 6.8 | 33±10 | >8 nightly | 18 mo 18% | Pulmonary function at 18 months FEV_1_ % (compared with baseline); Hospital admission Comparison to 18 months prior to the study; Days in hospital Comparison to 18 months prior to the study | Retrospective, historical controls, no patients lost to F/U
  LTOT | 32±13 NS
  Historical LTOT | 28±13 NS
  LTOT | 2.0±0.7 vs 1.0±0.9 | p<0.005
  Historical LTOT | 1.5±0.7 vs 1.5±1.1 | NS
  LTOT | 55±23 vs 18±20 | p<0.005
  Historical LTOT | 47±25 vs 38±29 | NS
Clini 1996 Italy | 18 mo of therapy | Inclusion: COPD on LTOT ≥ 18 months, chronic hypercapnia, PaCO_2_> 50, ≥ one hospital admission due to severe exacerbation in past 18 months Exclusion: ≥ 15% increase FEV_1_ | Historical LTOT N=29 Male: 53% Age: 66 | PaO_2_ 54± 6.8 PaCO_2_ 51 ± 4.5 | 31±12 | ND | 18 mo 17% | Pulmonary function at 18 months FEV_1_ % (compared with baseline); Hospital admission Comparison to 18 months prior to the study; Days in hospital Comparison to 18 months prior to the study | Retrospective, historical controls, no patients lost to F/U
Okubadejo 1996 UK | 6 mo of therapy | Inclusion: COPD FEV_1_<1.5L, PaO_2_ <7.3 when stable or a PaO_2_ <8.0 with evidence of cor pulmonale & ECG changes Exclusion: age <45, COPD exacerbation within past 3 wk | N=23 Male: 35% Age: 71 Median (47–82) | PaO_2_ 53± 6.0 PaCO_2_ 50± 9.0 | 40±17 | 17 | 6 mo 17% | Pulmonary function (n=19) FEV_1_% Predicted 38±17 Quality of life (n=19) | Baseline data for 19 survivors only, no patients lost to F/U
  SGRQ Total | NS
  SIP | NS
Heaney 1997 N Ireland | > 8 y study period | Inclusion: period 9/86–4/89, lifestyle or work severely limited, PaO_2_ < 6 kPa, no smoking; period > 4/89 FEV_1_ <1.51 L/FVC < 2.01, PaO_2_ < 7.3 kPa, PaCO_2_ > 6 kPa, edema, clinically stable, optimized therapy | N=178 Male: 62% Age: 64 | PaO_2_ 49 PaCO_2_ 49 | FEV_1_ L 0.93 | 10–15 (17%) > 15 (64%) | 10 mo 31% 20 mo 50% 60 mo 67% | | Ambidirectional F/U, no patients lost to F/U
Aida 1998 Japan | Ambidirectional 6 y, mean F/U 2.4 y | Inclusion: LTOT patients registered between 7/85 – 6/93, COPD, 40–80 y, PaO_2_ ≤ 60 mmHg - room air at rest, O_2_ > 15h/d | N=4,552 466 COPD Male*: 73% Age*: 69 *Subgroup data | PaO_2_ 50.3 PaCO_2_ 49 | ND | > 15 | 1 y 12.1% 2 y 37.9% 5 y 60.5% | | 1,740 institutions in registry, diagnosed by individual physician, overlapping population with Miyamoto 1995
Zielinski 1998 Poland | 6 y | Inclusion: stable hypoxemia (PaO_2_ < 55) assessed at steady state PaO2=56 to 65 | N=95 Male: 76% Age: 58 | PaO_2_ 55± 6 PaCO_2_ 48 ± 9 | FEV_1_ L 0.84±0.3 | 14 | 2 y 23% | “LTOT for 14 to 15h/d resulted in a long-term stabilization of pulmonary hypertension” 19 patients completed 6 years of LTOT | ---
Hjalmarsen 1999b Sweden | 3 mo | Inclusion: stable PaO_2_≤ 7.3 kPa or ≤8.0 kPa with coexisting polycythemia or cor pulmonale Exclusion: history of cardiac or cerebrovascular disease, history of psychiatric disorder by DSM-IV, metabolic or endocrine disorder, condition may influence cognitive performance | N=10 Male: 40% Age: 66 (51–74) | PaO_2_ 50±8.3 PaCO_2_ 53±11 | 38±12 | 18–24 | ND | Neuropsychological assessment No significant changes comparing baseline and 3 months after LTOT for the following: Trail Making Test Seashore Rhythm Test WMS-R CalCAP Grooved Pegboard STMS | No patients lost to F/U
Farrero 2001 Spain | 1 y F/U | Inclusion: primary COPD requiring LTOT, history of ≥6 mo LTOT, resides near hospital | N=62 Male: ND Age: 68 | PaO_2_ 50±7 PaCO_2_ 56±8 | 27±9 | ND | 1 y 34% | Emergency room visits (n=48, change over 1 y F/U) −1.6±2.0 Hospital admission rate (n=48) −1.3±1.7 Hospital stay (n=48) −18±25 Quality of life (n=16) NS for Chronic Respiratory Questionnaire Pulmonary function (n=48) | No patients lost to F/U
  | Pre | Post
  FEV_1_ % | 27±8 | 24±6 | p=0.01
Sergi 2002 Basel | 42 mo | Inclusion: stable PaO_2_ >60, FEV_1_ < 60% predicted & FEV_1_/VC<70% with TLC >80% predicted Exclusion: asthma, bronchiectasis, interstitial lung, heart disease, other serious disorder, hepatic cirrhosis or chronic renal failure | N=10 Male: ND Age: 66 | PaO_2_ 63±2.3 PaCO_2_ 44±2.3 See comments | 40±3.4 | >18 | ND | Pulmonary function; Data compared to baseline, not at start of LTOT. 9 were desaturators | Of 52 enrolled, 10 developed chronic respiratory failure requiring LTOT (PaO_2_<55), no ABG data reported at start of LTOT, LTOT started at 22±6.8 mo (median, 12–36 m) after enrollment
  FEV_1_ % | 34±2.2 | p<0.05
Bratel 2003 Sweden | 6.2±0.9 mo F/U | Inclusion: Moderate to severe airway obstruction <70% predicted, FEV_1_/VC<65% | N=12 Male: ND Age: 69 (n=19) | PaO_2_ 55±8 PaCO_2_ 44±6.7 | 29±18 | ≥ 16 (n=11) | ND | Pulmonary function FEV_1_ % 28±17 ns compared to baseline | No patients lost to F/U
Retrospective
McKeon 1987 Australia | 14 y F/U | Inclusion: LTOT guidelines established Oct 1982: COPD, right ventricular hypertrophy, secondary polycythemia, PaO_2_ < 56 mmHg & recurrent right heart failure; Prior to Oct 1982: LTOT qualification by means test | N=84 Male: ND Age: ND | ND | ND | ND | 1 y 6% 2 y 20% 5 y 64% | --- | Most pts already on LTOT at initiation of study, no patients lost to F/U
Corrado 1994 Italy | 4 y F/U | Inclusion: COPD with chronic respiratory insufficiency admitted 1984–1986 for acute respiratory failure | N=35 Male: 74% Age: 66 | PaO_2_ 52±5.7 PaCO_2_ 54±6.9 | 24±9.9 | >15 (15–18) | 1 y 6% 2 y 17% 3 y 37% 4 y 49% (graph estimates) | “LTOT of more than 15h/d seems to improve survival for at least 2 to 4 years.” | Baseline data at discharge, no patients lost to F/U
Buyse 1995 Belgium | 3 y F/U | Inclusion: adults with stable disease prescribed LTOT on 7/1/84 – 7/31/92 | COPD N=49 Male*: 77% Age*: 62 *Multiple diseases N=83 | PaO_2_ 50±7 PaCO_2_ 48±10 (n=46) | 33±17 Multiple diseases N=83 | ND | 1 y 13% 2 y 40% (n=15) | --- | 27% of sample had PaO_2_ 55–60
Miyamoto 1995 Japan | 7 y | Inclusion: LTOT pts registered between 7/85 – 6/93, PaO_2_ ≤ 55 mmHg - room air at rest, or ≤ 60 w/pulmonary hypertension or severe hypoxemia (≤ 55) during exercise or sleep Exclusion: PaO_2_ > 60 mmHg, FEV_1_/FVC > 70% | N=5,055 Male: 75% Age: 70 | PaO_2_ M 51±6.9 F 49±7.3 PaCO_2_ M 48±10 F 51±9.4 | ND | ND | 1 y 13% 2 y 25% 3 y 36% 5 y 58% | Survival M 4.8±9.9 vs F 5.28±0.18 p<0.05 NS for length of oxygen inhalation between sexes for LTOT pts > 15 h/d, n=unknown Significant (p<.05) difference between sexes for baseline PaO_2_ & PaCO_2_ values | 1,740 institutions in registry, diagnosed by individual physician, overlapping population with Aida 1998
Chailleux 1996 2003 France | 10 y | Inclusion: LTOT patients PaO_2_ ≤ 55 & >15h oxygen treated1/1984 –12/1992 | N=12,403 Chronic bronchitis 1,755 Asthma 551 Emphysema 1,556 Male: 84% Age: 69 | PaO_2_ M 53±7.5 F 53±7.2 PaCO_2_ M 47± 8.6 F 48± 8.3 | M 35±15 F 41±18 | ND | 1 y 25% 2 y 41% 5 y 70% (graph estimates) | In COPD: male sex, older age, lower BMI, FEV1% predicted, PaO_2_ and PaCO_2_ are independent negative prognostic factors for survival rate. Survival is slightly better for patients with bronchitis & asthma with permanent dyspnea and worse for those with emphysema
Hjalmarsen 1999a Sweden | 8 y F/U | Inclusion: PaO_2_ ≤ 7.3 kPa, LTOT following international prescription guidelines Exclusion: Interstitial pulmonary fibrosis, cancer, left heart failure | N=76 Male: 50% Age: 67 | PaO_2_ 48±0.75 (n=67) PaCO_2_ 53±1.5 (n=66) | 34±1.7 (n=59) | Prescribed >15 | 2 y 27% 5 y 50% | Survival | 1 withdrawal
  | [underlined: 2 y] | [underlined: 5 y]
  M | 56% | 30%
  F | 83% | 60% | p<0.005
Crockett 2001 Australia | 10 y F/U | Inclusion: Patients with chronic airflow limitation with LTOT between 1977 and 1999 Exclusion: asthma | N=505 Male: 49% Age: 70 | PaO_2_ M 53± 8.1 F 50.9±8.1 PaCO_2_ M 48±10 F 50±8.5 | FEV_1_ L M: 0.86±0.45 F: 0.65±0.25 | Prescribed > 15 for Belgian, Prescribed mean 19 for Swedish | 1 y 25% 2 y 49% 5 y 81% 10 y 99% | --- | ---
Ringbaek 2002 Denmark | 10 mo of therapy | Inclusion: COPD hypoxaemic patients from Danish Oxygen Registery | Total N=246 COT Male: 57% Age: 68 | PaO_2_ 48±5.3 PaCO_2_ 51±9.0 | 30±11 (n=114) | ≥15 | ND | Hospitalization; Hospital day were reduced by 23.8%, 43.5% and 31.2% LTOT is associated with a reduction in hospitalization, ns between groups | ---
  | Pre | Post
  Days | 23.7±24.5 | 13.4± 22.7 | p<0.001
  Admission | 2.1±1.9 | 1.6±2.2 | p<0.001
Ringbaek 2002 Denmark | 10 mo of therapy | Inclusion: COPD hypoxaemic patients from Danish Oxygen Registery | NCOT Male: 49% Age: 72 | PaO_2_ 48±6.8 PaCO_2_ 49±11 | 30±11 (n=114) | < 15 | ND | Hospitalization; Hospital day were reduced by 23.8%, 43.5% and 31.2% LTOT is associated with a reduction in hospitalization, ns between groups | ---
Demirel 2003 Turkey | 17±15 mo (1–71) of therapy | Inclusion: Patients received COT COPD by ATS with ABG data | N=127 124 COPD (97%) Male: 73% Age: 62 | PaO_2_ 52± 11 PaCO_2_ 50±9.6 | 31±12 | 12 (11%) > 15 (43%) | 5.5% F/U interval unknown | 77% patients stated that they had benefited from therapy. “Continuous oxygen therapy is an effective treatment modality but patient compliance remains a problem” | ABG data analyzed for 86 patients, 6 centers, 7 lost to F/U

Evidence Table 4 Cohort studies of LTOT for COPD patients with PaO_2_ between 56 and 59 mmHg

Study Year Country | Study design | | Population | Baseline | | O_2_ therapy: hours/day | Outcomes | | Comments
Study Year Country | Duration | Inclusion / exclusion | Population | PaO_2_ PaCO_2_ mmHg | FEV_1_ (% Predicted) | O_2_ therapy: hours/day | Mortality | Other outcomes | Comments
Prospective
Sliwinski 1992 1993 Poland | 2 y of therapy | Inclusion: PaO_2_ < 55 mmHg, or PaO_2_ 55–65 with pulmonary hypertension, right ventricular hypertrophy, elevated hematocrit Exclusion: conditions influencing survival (sys hypertension, IHD, left heart failure, liver cirrhosis, renal failure, DM, cancer | N=46 Male: 83% Age: 55 | PaO_2_ 57±6 PaCO_2_ 48±9 | FEV_1_ L 0.84±0.32 | 15 | 1 y 8.7% 2 y 33% | Pulmonary function FEV_1_ 0.7±0.3 p<0.01 (compare with baseline at 2 y, n=19) | ---
Sandek 2001 Sweden | 6 mo F/U | Inclusion: irreversible airflow obstruction FEV_1_ %P < 70 & FEV_1_/FVC ratio <70%, 2 PaO_2_ measures < 7.3 kPa (3 wk apart) or 7.3–7.9 w/chronic right heart insufficiency | N=14 Male: ND Age: 69 (45–74) | PaO_2_ 58 (46–63) PaCO_2_ 41 (30–49) Median | 34 Median (17–68) | 16 | ND | Pulmonary function FEV_1_ % 32 (14–66) Median | Data inconsistent, statistical methods used inappropriate for data, no patients lost to F/U
Retrospective
Hjalmarsen 1999a Sweden | 8 y F/U | Inclusion: PaO_2_ ≥ 7.4 kPa, LTOT following international prescription guidelines Exclusion: Interstitial pulmonary fibrosis, cancer, left heart failure | N=48 Male: 79% Age: 69 | PaO_2_ 62±0.75 PaCO_2_ 44±1.5 | 33±2.0 (SE) (n=43) | Prescribed >15 | 24 mo 22% 60 mo 60% | Survival 50% survival: | 1 withdrawal
  Male | 4.2 y
  Female | 5.1 y