# REFERENCES

Aida A, Miyamoto K, Nishimura M, Aiba M, Kira S, Kawakami Y. Prognostic value of hypercapnia in patients with chronic respiratory failure during long-term oxygen therapy. Am J Respir Crit Care Med. 1998;158:188-193. [pmid: 9655728].
Ashutosh K, Mead G, Dunsky M. Early effects of oxygen administration and prognosis in chronic obstructive pulmonary disease and cor pulmonale. Am Rev Respir Dis. 1983;127:399-404. [pmid: 6838047].
Borak J, Sliwinski P, Tobiasz M, Gorecka D, Zielinski J. Psychological status of COPD patients before and after one year of long-term oxygen therapy. Monaldi Arch Chest Dis. 1996;51:7-11. [pmid: 8901313].
Bratel T, Ljungman S, Runold M, Stenvinkel P. Renal function in hypoxaemic chronic obstructive pulmonary disease: effects of long-term oxygen treatment. Respir Med. 2003;97:308-316. [pmid: 12693791].
Buyse B, Demedts M. Long-term oxygen therapy with concentrators and liquid oxygen. Acta Clinica Belgica. 1995;50:149-157. [pmid: 7631530].
Chailleux E, Fauroux B, Binet F, Dautzenberg B, Polu JM. Predictors of survival in patients receiving domiciliary oxygen therapy or mechanical ventilation. A 10-year analysis of ANTADIR Observatory. Chest. 1996;109:741-749. [pmid: 8617085].
Chailleux E, Laaban JP, Veale D. Prognostic value of nutritional depletion in patients with COPD treated by long-term oxygen therapy: data from the ANTADIR observatory. Chest. 2003;123:1460-1466. [pmid: 12740261].
Chang TT, Lipinski CA, Sherman HF. A hazard of home oxygen therapy. J Burn Care Rehab. 2001;22:71-74.
Chaouat A, Weitzenblum E, Kessler R, Charpentier C, Enrhart M, Schott R, et al. A randomized trial of nocturnal oxygen therapy in chronic obstructive pulmonary disease patients. Eur Respir J. 1999;14:1002-1008. [pmid: 10596681].
Clini E, Vitacca M, Foglio K, Simoni P, Ambrosino N. Long-term home care programmes may reduce hospital admissions in COPD with chronic hypercapnia. Eur Respir J. 1996;9:1605-1610. [pmid: 8866580].
Continuous or nocturnal oxygen therapy in hypoxemic chronic obstructive lung disease: a clinical trial. Nocturnal Oxygen Therapy Trial Group. Ann Intern Med. 1980;93:391-398. [pmid: 6776858].
Corrado A, De Paola E, Messori A, Bruscoli G, Nutini S. The effect of intermittent negative pressure ventilation and long-term oxygen therapy for patients with COPD. A 4-year study. Chest. 1994;105:95-99. [pmid: 8275794].
Crockett AJ, Cranston JM, Moss JR, Alpers JH. Survival on long-term oxygen therapy in chronic airflow limitation: from evidence to outcomes in the routine clinical setting. Internal Medicine Journal. 2001;31:448-454. [pmid: 11720057].
Crockett AJ, Cranston JM, Moss JR, Alpers JH. Domiciliary oxygen for chronic obstructive pulmonary disease (Cochrane Review). The Cochrane Library, Issue 3. Oxford. Update Software. 2003.
Cuvelier A, Nuir JF, Chakroun N, Aboab J, Onea G, Benhamou D. Refillable oxygen cylinders may be an alternative for ambulatory oxygen therapy in COPD. Chest. 2002;122:451-456. [pmid: 12171816].
Dallari R, Barozzi G, Pinelli G, Merighi V, Grandi P, Manzotti M, et al. Predictors of survival in subjects with chronic obstructive pulmonary disease treated with long-term oxygen therapy. Respiration. 1994;61:8-13. [pmid: 8177977].
Demirel H, Demir T, Umut S. Retrospective evaluation of patient compliance in continuous oxygen therapy. Respiration. 2003;70:149-153. [pmid: 12740511].
Dubois P, Jamart J, Machiels J, Smeets F, Lulling J. Prognosis of severely hypoxemic patients receiving long-term oxygen therapy. Chest. 1994;105:469-474. [pmid: 8306749].
Dubois P, Machiels J, Smeets F, Delwiche JP, Lulling J. CO transfer capacity as a determining factor of survival for severe hypoxaemic COPD patients under long-term oxygen therapy. Eur Respir J. 1990;3:1042-1047. [pmid: 2289552].
Farrero E, Escarrabill J, Prats E, Maderal M, Manresa F. Impact of a hospital-based home-care program on the management of COPD patients receiving long-term oxygen therapy. Chest. 2001;119:364-369. [pmid: 11171710].
Fleetham JA, Bradley CA, Kryger MH, Anthonisen NR. The effect of low flow oxygen therapy on the chemical control of ventilation in patients with hypoxemic COPD. Am Rev Respir Dis. 1980;122:833-840. [pmid: 6779682].
Gorecka D, Gorzelak K, Sliwinski P, Tobiasz M, Zielinski J. Effect of long-term oxygen therapy on survival in patients with chronic obstructive pulmonary disease with moderate hypoxaemia. Thorax. 1997;52:674-679. [pmid: 9337824].
Gorecka D, Sliwinski P, Zielinski J. Adherence to entry criteria and one year experience of long-term oxygen therapy in Poland. Eur Respir J. 1992;5:848-852. [pmid: 1499709].
Heaney LG, Buick JB, Lowry RC, MacMahon J. Prescription of oxygen concentrators and survival in Northern Ireland. Ulster Med J. 1997;66:86-91. [pmid: 9414936].
Heaton RK, Grant I, McSweeny AJ, Adams KM, Petty TL. Psychologic effects of continuous and nocturnal oxygen therapy in hypoxemic chronic obstructive pulmonary disease. Arch Intern Med. 1983;143:1941-1947. [pmid: 6625781].
Hjalmarsen A, Melbye H, Wilsgaard T, Holmboe JH, Opdahl R, Viitanen M. Prognosis for chronic obstructive pulmonary disease patients who receive long-term oxygen therapy. Int J Tubercul Lung Dis. 1999a;3:1120-1126.
Hjalmarsen A, Waterloo K, Dahl A, Jorde R, Viitanen M. Effect of long-term oxygen therapy on cognitive and neurological dysfunction in chronic obstructive pulmonary disease. Eur Neurol. 1999b;42:27-35. [pmid: 10394045].
Krop HD, Block AJ, Cohen E. Neuropsychologic effects of continuous oxygen therapy in chronic obstructive pulmonary disease. Chest. 1973;64:317-322. [pmid: 4749376].
Lahdensuo A, Ojanen M, Ahonen A, Laitinen J, Poppius H, Salorinne Y, et al. Psychosocial effects of continuous oxygen therapy in hypoxaemic chronic obstructive pulmonary disease patients. Eur Respir J. 1989;2:977-980. [pmid: 2606199].
Lin CC. Comparison between nocturnal nasal positive pressure ventilation combined with oxygen therapy and oxygen monotherapy in patients with severe COPD. Am J Respir Crit Care Med. 1996;154(2:Pt 1):353-358. [pmid: 8756806].
Long term domiciliary oxygen therapy in chronic hypoxic cor pulmonale complicating chronic bronchitis and emphysema. Report of the Medical Research Council Working Party. Lancet. 1981;1(8222):681-686. [pmid: 6110912].
McKeon JL, Saunders NA, MurreeAllen K. Domiciliary oxygen: rationalization of supply in the Hunter region from 1982–1986. Medical J Australia. 1987;146:73-78.
Miyamoto K, Aida A, Nishimura M, Aiba M, Kira S, Kawakami Y. Gender effect on prognosis of patients receiving long-term home oxygen therapy. The Respiratory Failure Research Group in Japan. Am J Respir Crit Care Med. 1995;152:972-976. [pmid: 7663812].
Okubadejo AA, Paul EA, Jones PW, Wedzicha JA. Does long-term oxygen therapy affect quality of life in patients with chronic obstructive pulmonary disease and severe hypoxaemia?. Eur Respir J. 1996;9:2335-2339. [pmid: 8947081].
OswaldMammosser M, Weitzenblum E, Quoix E, Moser G, Chaouat A, Charpentier C, et al. Prognostic factors in COPD patients receiving long-term oxygen therapy. Importance of pulmonary artery pressure. Chest. 1995;107:1193-1198. [pmid: 7750305].
Petty TL, Bliss PL. Ambulatory oxygen therapy, exercise, and survival with advanced chronic obstructive pulmonary disease (the Nocturnal Oxygen Therapy Trial revisited). Respir Care. 2000;45:204-211. [pmid: 10771792].
Ringbaek TJ, Viskum K, Lange P. Does long-term oxygen therapy reduce hospitalisation in hypoxaemic chronic obstructive pulmonary disease?. Eur Respir J. 2002;20:38-42. [pmid: 12166578].
Sandek K, Bratel T, Hellstrom G, Lagerstrand L. Ventilation-perfusion inequality and carbon dioxide sensitivity in hypoxaemic chronic obstructive pulmonary disease (COPD) and effects of 6 months of long-term oxygen treatment (LTOT). Clin Physiol. 2001;21:584-593. [pmid: 11576160].
Sergi M, Rizzi M, Andreoli A, Pecis M, Bruschi C, Fanfulla F. Are COPD patients with nocturnal REM sleep-related desaturations more prone to developing chronic respiratory failure requiring long-term oxygen therapy?. Respiration. 2002;69:117-122. [pmid: 11961424].
Simonds AK, Elliott MW. Outcome of domiciliary nasal intermittent positive pressure ventilation in restrictive and obstructive disorders. Thorax. 1995;50:604-609. [pmid: 7638799].
Sliwinski P, Hawrylkiewicz I, Gorecka D, Zielinski J. Acute effect of oxygen on pulmonary arterial pressure does not predict survival on long-term oxygen therapy in patients with chronic obstructive pulmonary disease. Am Rev Respir Dis. 1992;146:665-669. [pmid: 1519845].
Sliwinski P, Hawrylkiewicz I, Gorecka D, Zielinski J. The acute effect of oxygen on pulmonary arterial pressure does not predict survival on long-term oxygen therapy in COPD patients. Monaldi Arch Chest Dis. 1993;48:451-452. [pmid: 8312902].
Stewart BN, Hood CI, Block AJ. Long-term results of continuous oxygen therapy at sea level. Chest. 1975;68:486-492. [pmid: 1175404].
Strom K, Boe J. Quality assessment and predictors of survival in long-term domiciliary oxygen therapy. The Swedish Society of Chest Medicine. Eur Respir J. 1991;4:50-58. [pmid: 2026239].
Strom K. Oral corticosteroid treatment during long-term oxygen therapy in chronic obstructive pulmonary disease: a risk factor for hospitalization and mortality in women. Respir Med. 1998;92:50-56. [pmid: 9519225].
Strom K. Survival of patients with chronic obstructive pulmonary disease receiving long-term domiciliary oxygen therapy. Am Rev Respir Dis. 1993;147:585-591. [pmid: 8442591].
Tarpy SP, Celli BR. Long-term oxygen therapy. N Engl J Med. 1995;333:710-714. [pmid: 7637750].
Vergeret J, Brambilla C, Mounier L. Portable oxygen therapy: use and benefit in hypoxaemic COPD patients on long-term oxygen therapy. Eur Respir J. 1989;2:20-25. [pmid: 2707399].
Weitzenblum E, Oswald M, Apprill M, Ratomaharo J, Kessler R. Evolution of physiological variables in patients with chronic obstructive pulmonary disease before and during long-term oxygen therapy. Respiration. 1991;58(3–4):126-131. [pmid: 1745843].
Weitzenblum E, Sautegeau A, Ehrhart M, Mammosser M, Pelletier A. Long-term oxygen therapy can reverse the progression of pulmonary hypertension in patients with chronic obstructive pulmonary disease. Am Rev Respir Dis. 1985;131:493-498. [pmid: 3922267].
Zielinski J, Tobiasz M, Hawrylkiewicz I, Sliwinski P, Palasiewicz G. Effects of long-term oxygen therapy on pulmonary hemodynamics in COPD patients: a 6-year prospective study. Chest. 1998;113:65-70. [pmid: 9440570].