# Summary

The current review supports the following conclusions regarding the specific questions posed by CMS.

1. The performance of the tests measuring hemoglobin A1c in the point of care setting and the laboratory setting: Though there are some differences between point of care HbA1c testing devices with regard to susceptibility to interference and other performance characteristics, it seems reasonable to say that devices which satisfy criteria for accuracy and precision disseminated by the National Glycohemoglobin Standardization Program (NGSP) Certification Protocol are functionally equivalent to conventional devices. The same may not be supported for devices that do not satisfy these standards. While operator dependency is less of an issue for devices that are CLIA-waived, the relationship between test performance and operator skill has not been well established.

2. The influence of performing HbA1c at the point of care on patient management decisions compared to performing the test in the laboratory setting: The evidence suggests that point of care HbA1c testing can effect management decisions, such as appropriate intensification of therapy for patients with substantial elevations of HbA1c (> 8.0%), intensification of therapy in patients who have mild hyperglycemia if they also have an elevated HbA1c level; and diminished inappropriate intensification of therapy for patients under good control by HbA1c, but who have a point of care glucose result that is discordantly high. This underlines the importance of the conscientiousness of the provider in achieving the potential benefits of HbA1c point of care testing.

3. Impact of performing HbA1c testing at the point of care on clinical outcomes for Medicare beneficiaries, compared to performing the test in a laboratory setting: No direct evidence was found that addresses this question. However, we examined this issue indirectly by assessing the evidence regarding 1) impact on HbA1c improvement, and 2) impact of HbA1c improvement on clinical outcomes. Regarding the first issue, performing HbA1c testing at the point of care appears to confer an improvement in HbA1c results the magnitude of which is in the range of a decrease in HgbA1c of at least 0.2% and perhaps as high as 0.8%. However, available data indicates that these results may not necessarily be durable or generalizable. Few data are available beyond six months, and twelve-month data from one study suggest a smaller effect on HgbA1c of point of care at twelve than at six-months. This finding is consistent with the hypothesis that point of care testing primarily accelerates therapeutic changes, which implies that its impact will diminish over time. Moreover, the impact may be related by factors such as the current level of glycemic control by the individual patient and the degree of organization of the clinic in which testing will be done (e.g., as reflected by systematic efforts at quality improvement). Regarding the second issue, trials support a relationship between improved HbA1c and clinical outcomes. From these data, it appears that a modest benefit of point of care testing on glycemic control (an improvement on the order of 0.5%) would be expected to be associated with a reduction in the following events per 1,000 patient-years: 2 deaths, 1 myocardial infarction, 1.5 lower-limb amputations or other significant manifestation of peripheral vascular disease, 10 microvascular complications, and 2 cataract extractions.

4. Impact of point of care HbA1c testing on health care expenditures: From a modest literature it may reasonable to conclude that point of care HbA1c testing per se has no impact on health care resource use within the first year of point of care testing, even if the testing results in improved glycemic control. There is some evidence that if improved glycemic control can be achieved, irrespective of whether HbA1c is measured in the laboratory or at point-of-care, some economic benefits in terms of reduced health care resource use can be achieved, and these are more significant in patients with diabetes-related long-term complications, and over three years of glycemic control.

A variety of significant issues related to health care expenditure are not addressed by available US literature, including the magnitude of health care resources used in providing point of care testing (such as nursing time to perform testing, greater number of tests performed, capital equipment costs) immediate cost offsets (realized and not realized, such as decreased time to follow up laboratory results that appear hours to days after the clinic visit) as well as long-term cost offsets which have major potential societal impact (such as changes in the rates of preventable events associated with poor glycemic control.)