# Overview

Point of care laboratory testing is the most rapidly growing segment of the clinical laboratory market, with a projected increase in sales from $4.2 billion to $6.2 billion between 2002 and 2007, representing an 8.1% increase.1 The rising prevalence of this technology will present the Centers for Medicare and Medicaid Services (CMS) with a variety of issues surrounding the quality of care and cost effectiveness for Medicare beneficiaries. CMS has requested objective data in the form of technology assessments to better inform coverage and payment decisions that CMS will need to make in the future.

## 1.1 Salience of a Technology Assessment of Point of Care Hemoglobin A1c Testing Devices

This report represents the first phase of this project – an assessment of the use of hemoglobin A1c (HbA1c) in the point of care environment. A review of this topic is particularly salient for three reasons. First, diabetes induces major health and economic burdens, particularly in the Medicare population. Diabetes is a chronic disease that affects an estimated 18.2 million people in the United States, is associated with protean manifestations such as heart disease, blindness, kidney failure, and limb loss. Diabetes is estimated to cost in excess of $132 billion per year in medical treatment and productivity loss.2 Over half of these medical costs are incurred by individuals over age 65 years.3

A second reason a review of point of care HbA1c devices is especially appropriate is that HbA1c measurement has been shown to influence clinical management and health outcomes for individuals with diabetes. HbA1c is the most prevalent of several chemically distinct species of glycated hemoglobins resulting from the non-enzymatic reaction between glucose and the free amino groups of hemoglobin.4 This reaction is irreversible and the proportion of hemoglobin in the red blood cells in the form of HbA1c depends on glucose concentration over time.5 HbA1c has become the “gold standard” for assessing metabolic control.6 The value of HbA1c testing in the management of individuals with diabetes can be inferred from trials of aggressive glucose control, in particular the Diabetes Control and Complications Trial (DCCT) and the U.K. Prospective Diabetes Study (UKPDS).7, 8 Based on these and other studies, it appears that more successful management of glucose as measured by HbA1c level is directly related to reduction in diabetic complications.9

Third, assessment of HbA1c point of care devices is salient because of increasing number of devices on the market, especially devices that satisfy emerging standards for accuracy and precision. Of diagnostic tests approved for point of care use by the Food and Drug Administration (FDA), devices for measurement of HbA1c are amongst the most common.10 Further, several manufacturers have demonstrated compliance with the Certification Protocol disseminated by the National Glycohemoglobin Standardization Program (NGSP).11 FDA-approved HbA1c test point of care devices that also satisfy NGSP standards are listed in Table 1. The NGSP Certification Protocol is provided in Appendix A.

Table 1 HbA1c test devices that are approved by the FDA for point of care use and satisfy the NGSP Certification Protocol.

Device | CLIA category
Axis-Shield Nycocard | Moderate complexity
Bayer DCA 2000 | Waived
Bio-Rad D-10 | Moderate complexity
Bio-Rad Dia-STAT | Moderate complexity
Drew Scientific DS5 (the same device as the Bio-Rad Dia-STAT except for labeling) | Moderate complexity
Metrika A1c Now (also available over the counter) | Waived
Provalis Glycosal (Bio-Rad MicroMat and Cholestech GDX) | Waived

CLIA – Clinical Laboratory Improvement Amendment;

Moderate complexity – subject to specific requirements for quality control, quality assurance, personnel qualifications and responsibilities, and proficiency testing with routine biennial inspections;

Waived – exempt from quality standards and are defined as simple tests having an insignificant risk of an erroneous result.

## 1.2 Questions Posed by CMS Regarding Point of Care HbA1c Testing Devices

The present evaluation of point of care HbA1c testing devices was designed to respond to four specific questions posed by CMS:

1. What is the evidence on the performance of the tests measuring hemoglobin A1c in the point of care setting and the laboratory setting?
2. Is there evidence that performing hemoglobin A1c at the point of care influences patient management decisions compared to performing the test in the laboratory setting?
3. Is there direct evidence (from clinical studies) or indirect evidence (e.g., from clinical studies integrated using a model) that performing hemoglobin A1c at the point of care results in better clinical outcomes for Medicare beneficiaries, such as reduced length of stay, decreased morbidity and mortality, and improved quality of life, compared to performing the test in a laboratory setting?
4. Is there evidence quantifying the impact on health care expenditures?

In the following section, we describe the general methods of this assessment.