# Methods

## 2.1 Search Strategy

We identified relevant articles from citations in a recent systematic review.12 These included six clinical studies comparing point of care glycated hemoglobin testing with standard laboratory testing13–18 and four studies comparing the accuracy of point of care glycated hemoglobin and standard laboratory tests for hemoglobin A1c.19–22

Medical Subject Heading (MeSH) coding of these articles was examined for relevant terms; however, there was little consistency in terms used for the point of care testing concept. Preliminary searches designed using various combinations of the following MeSH terms did not attain reasonable specificity (Diabetes Mellitus, Hemoglobin A, Glycosylated) or sensitivity (Point of Care Systems).

We used these seed articles to identify additional relevant citations using two strategies: 1) articles that cited any of the seed articles using the Web of Science citation index database; and 2) articles identified using the “Relevant Citations” search feature from the PubMed citation of each seed article. These searches were updated to April 2005.

In addition we queried several experts in the field and evaluated citations of included studies, and reviewed publicly available FDA documentation on relevant devices.

Findings are presented by question, focusing on study characteristics that relate to the potential for biased inference (e.g., categorizing the study as a randomized controlled trial, a prospective cohort study, or an observational study), and quantitative study results. Note that we did not attempt formal extrapolations beyond the published evidence, such as a new decision, a cost effectiveness model, or a business case analysis.