# Effects of frequently encountered Hb variants and derivatives on GHB measurement

Interference (Yes/No)

Method (listed in alphabetical order by manufacturer) | Hb C trait | Hb S trait | Hb E trait | Elevated HbF | Carbamyl-Hb
*Axis-Shield Nycocard (Primus Nycocard) | No 5 | No 5 | - | - | -
*Bayer DCA 2000 | No 1, 6, 7 | No 1, 6 | No 1, 8–9 | - | No 4, 10
Beckman Diatrac | Yes 1,2,11 | Yes 1,2,11 | - | Yes 11 | Yes 1,11
*Beckman Synchron CX7 | No 5 | No 5 | - | - | -
*Bio-Rad D-10 | Yes 33 | No 33 | - | - | -
*Bio-Rad DiaSTAT | No 33 | Yes 33 | - | - | -
*Bio-Rad Variant A1c | No 1–2 | Yes 1,2 | No 1,8 | - | Yes 1,4,12,13,15
*Bio-Rad Variant GHb | No 5 | No 5 | - | - | -
*Bio-Rad Variant II A1c | Yes 33/No 5 | Yes 33/No 5 | - | No (≤24% HbF)t | No 12
*Dade Dimension RxL | No 33 | No 33 | - | - | -
*Drew Scientific DS5 | No 33 | Yes 33 | - | - | -
Helena Glyco-Tek | Yes 5,6 | No 5,6 | - | - | -
*Menarini HA8140 | No 5 | Yes 5 | Yes 1,17 | No 1,17 | Yes/No 1,4,18,19
*Menarini HA8160 | No 33 | No 33 | - | - | -
*Metrika A1c Now | Yes 33 | Yes 33 | - | - | -
*Primus CLC 330/385 | No 1–2 | No 1–2 | No 1,8 | - | No 1,4,10,20
*Primus PDQ | No 33 | No 33 | - | - | -
*Provalis Glycosal (Bio-Rad MicroMat) | Yes5 | No5 | - | - | -
*Roche Cobas Integra | Yes 5 | Yes 5 | - | - | -
*Roche Tina-quant II | No 1,2,21 | No 1,2,21 | No 1,21 | No (≤30% HbF) 21 | No 1,4,18
*Roche Unimate | Yes 1,22 | Yes 1,22 | - | - | No 1,4,12
*Tosoh A1c 2.2 Plus | No 1,2,33 | No 1,2,33 | Yes 1,8 | - | Yes/No 1,4,12,15, 18,23,24
*Tosoh G7 | No 33 | No 33 | - | - | -

1) * indicates an NGSP certified method (as of July 2004); 2) t The manufacturer has recently lowered the level at which they claim no interference from 30% HbF to 15% HbF; 3) Yes/No indicates that there is conflicting data in the literature. The indicator in bold is the opinion of the NGSP based on review of the literature cited. NOTE Many other publications have been reviewed. Only those with conclusions that are reasonably supported by data are included. For ion-exchange HPLC methods, interference from Hb variants and adducts may be dependent on the lot of reagents used (2).