# Factors that interfere with GHB (HbA1c) Test Results11

UPDATED 06/04

Hemoglobin Variants and Derivatives: Genetic variants (e.g. HbS trait, HbC trait) and chemically modified derivatives of hemoglobin (e.g. carbamylated Hb in patients with renal failure, acetylated Hb in patients taking large amounts of aspirin) can affect the accuracy of GHB measurements. The effects vary depending on the specific Hb variant or derivative and the specific GHB method. Appendix C contains information for most of the commonly used GHB methods for the some of the more common Hb variants and derivatives. Interferences from less common Hb variants and derivatives are discussed in Bry, et al (1) When selecting an assay method, laboratories should take into consideration characteristics of the patient population served, (i.e., high prevalence of hemoglobinopathies or renal failure).

Shortened Erythrocyte Survival: Any condition that shortens erythrocyte survival or decreases mean erythrocyte age (e.g., recovery from acute blood loss, hemolytic anemia) will falsely lower GHB test results regardless of the assay method used (25). GHB results from patients with HbSS, HbCC, and HbSC must be interpreted with caution given the pathological processes, including anemia, increased red cell turnover, transfusion requirements, that adversely impact GHB as a marker of long-term glycemic control. Alternative forms of testing such as glycated serum protein (fructosamine) should be considered for these patients.

Other factors: Vitamins C and E are reported to falsely lower test results, possibly by inhibiting glycation of hemoglobin (26,27); vitamin C may increase values with some assays (27). Iron-deficiency anemia is reported to increase test results (28). Hypertriglyceridemia, hyperbilirubinemia, uremia (see carbamylated Hb in Appendix C), chronic alcoholism, chronic ingestion of salicylates, and opiate addiction are reported to interfere with some assay methods, falsely increasing results (4,6,10,12–13,15,18–20, 23–24, 29–32).