# List of Acronyms/Abbreviations

BMI: Body Mass Index
CI: Confidence Interval
CLIA: Clinical Laboratory Improvement Amendment
CMS: Centers for Medicare and Medicaid Services
CPRL: Central Primary Reference Laboratory
CV: Total imprecision
DCCT: Diabetes Control and Complications Trial
DM: Diabetes Mellitus
FDA: Food and Drug Administration
FDAMA: Food and Drug Administration Modernization Act
GHB: Gamma Hydroxybutyrate
HbA1c: Hemoglobin A1c
HbCC: Hemoglobin CC
HbSC: Hemoglobin SC
HbSS: Hemoglobin SS
HMO: Health Maintenance Organization
HPLC: High Performance Liquid Chromatography
ICD-9-CM: International Classification of Diseases, ninth revision, Clinical Modification
LAB: Laboratory
MeSH: Medical Subject Heading
MI: Myocardial Infarction
n: Sample Size
NACB: National Academy of Clinical Biochemistry
NCCLS EP5-A: National Committee for Clinical Laboratory Standards EP5-A Guidelines
NETCORE: Internet Service Provider
NGSP: National Glycohemoglobin Standardization Program
NR: Not reported
NS: Not significant
OHA: Oral hypoglycaemic agent
OR: Odds ratio
p: P-value
POCT: Point of care testing
PVD: Peripheral vascular disease
r: Correlation
RCT: Randomized Clinical Trial
SD: Standard deviation
SEM: Standard error of the mean
SRL: Survival Research Labs
U: Units
UKPDS: U. K. Prospective Diabetes Study