# References

1 Rajan M. Business Communications Company, Inc for Immediate Release. RB-168 The U.S. Clinical Diagnostic Equipment Market. 2003. January. Available at: http://www.bccresearch.com/editors/RB-168.html. Last accessed: June 2, 2005.
2 American Diabetes Association. Diabetes Statistics. Available at: http://www.diabetes.org/diabetes-statistics.jsp. Last accessed: April 22, 2005.
3 Hogan P, Dall T, Nikolov P. American Diabetes Association. Economic costs of diabetes in the US in 2002. Diabetes Care. 2003;26(3):917-932. [pmid: 12610059].
4 John WG, Bullock DG, MacKenzie F. Methods for the analysis of glycated haemoglobins: what is being measured?. Diabetic Medicine. 1992;9(1):15-19. [pmid: 1551305].
5 Colman PG, Goodall GI, Garcia-Webb P, Williams PF, Dunlop ME. Glycohaemoglobin: a crucial measurement in modern diabetes management. Progress towards standardisation and improved precision of measurement. Australian Diabetes Society, the Royal College of Pathologists of Australasia and the Australasian Association of Clinical Biochemists. Medical Journal of Australia. 1997;167(2):96-98. [pmid: 9251696].
6 Jeppsson JO, Jerntorp P, Almer LO, et al. Capillary blood on filter paper for determination of HbA1c by ion exchange chromatography. Diabetes Care. 1996;19(2):142-145. [pmid: 8718434].
7 The Diabetes Control and Complications Trial Research Group. The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. New England Journal of Medicine. Sep. 30. 1993;329(14):977-986. [pmid: 8366922].
8 UK Prospective Diabetes Study (UKPDS) Group. Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). Lancet. Sep. 12. 1998;352(9131):854-865. [pmid: 9742977].
9 Golden S, Boulware L, Brancati F, Berkenblit G, Chander G, Marinopoulos S, et al. Use of glycated hemoglobin and microalbuminuria in the monitoring of diabetes mellitus. Evidence Report/Technology Assessment no. 84. Rockville, MD. Agency for Healthcare Research and Quality, U.S., Department of Health and Human Services. 2003.
10 U.S. Food and Drug Administration. Getting to Market with a Medical Device. Available at: http://www.fda.gov/cdrh/devadvice/3122.html#link_2. Last accessed April 22, 2005.
11 National Glycohemoglobin Standardization Program. Purpose of NGSP. Available at: http://web.missouri.edu/~diabetes/ngsp/index.html. Last accessed April 22, 2005.
12 Aarsand AK, Alter D, Frost SJ, et al. NACB Laboratory Medicine Practice Guidelines/ Evidence-based Practice for POCT/ Diagnosis and Management of Diabetes Mellitus. 2004.
13 Cagliero E, Levina EV, Nathan DM. Immediate feedback of HbA1c levels improves glycemic control in type 1 and insulin-treated type 2 diabetic patients. Diabetes Care. 1999;22(11):1785-1789. [pmid: 10546008].
14 Ferenczi A, Reddy K, Lorber DL. Effect of immediate hemoglobin A1c results on treatment decisions in office practice. Endocr Pract. 2001;7(2):85-88. [pmid: 11421550].
15 Grieve R, Beech R, Vincent J, et al. Near patient testing in diabetes clinics: appraising the costs and outcomes. Health Technol Assess. 1999;3(15):1-74. [pmid: 10632625].
16 Holman RR, Jelfs R, Causier PM, et al. Glycosylated haemoglobin measurement on blood samples taken by patients: an additional aid to assessing diabetic control. Diabet Med. 1987;4(1):71-73. [pmid: 2951227].
17 Miller CD, Barnes CS, Phillips LS, et al. Rapid A1c availability improves clinical decision-making in an urban primary care clinic. Diabetes Care. 2003;26(4):1158-1163. [pmid: 12663590].
18 Thaler LM, Ziemer DC, Gallina DL, et al. Diabetes in urban African-Americans. XVII. Availability of rapid HbA1c measurements enhances clinical decision-making. Diabetes Care. 1999;22(9):1415-1421. [pmid: 10480502].
19 Carter JS, Houston CA, Gilliland SS, et al. Rapid HbA1c testing in a community setting. Diabetes Care. 1996;19(7):764-767. [pmid: 8799636].
20 Guerci B, Durain D, Leblanc H, et al. Multicentre evaluation of the DCA 2000 system for measuring glycated haemoglobin. Diabetes & Metabolism. 1997;23(3):195-201. [pmid: 9233995].
21 John WG, Edwards R, Price CP. Laboratory evaluation of the DCA 2000 clinic HbA1c immunoassay analyser. Ann Clin Biochem. 1994;31(Pt 4):367-370. [pmid: 7979104].
22 Pope RM, Apps JM, Page MD, et al. A novel device for the rapid in-clinic measurement of haemoglobin A1c. Diabet Med. 1993;10(3):260-263. [pmid: 8485958].
23 Guthrie R, Hellman R, Kilo C, et al. A multisite physician’s office laboratory evaluation of an immunological method for the measurement of HbA1c. Diabetes Care. 1992;15(11):1494-1498. [pmid: 1468275].
24 National Glycohemoglobin Standardization Program (NGSP). List of NGSP Certified Laboratories (updated 5/05, listed by date certified). Available at: http://www.missouri.edu/~diabetes/ngsp/labs.pdf. Accessed: June 2, 2005.
25 National Glycohemoglobin Standardization Program (NGSP). NGSP Level I Laboratory Information Packet. Available at: http://web.missouri.edu/~diabetes/ngsp/cert/ref_info.html. Accessed: June 2, 2005.
26 U.S. Food and Drug Administration, Center for Devices and Radiological Health. Guidance for Clinical Laboratory Improvement Amendments of 1998 (CLIA) Criteria for Waiver, Draft Guidance for Industry and FDA Applications. 2001. March. Available at: http://www.fda.gov/cdrh/ode/guidance/1147.html. Accessed: June 2, 2005.
27 Stivers CR, Baddam SR, Clark AL, Ammirati EB, Irvin BR, Blatt JM. A miniaturized self-contained single-use disposable quantitative test for hemoglobin A1c in blood at the point of care. Diabetes Technology & Therapeutics. 2000;2(4):517-526. [pmid: 11469613].
28 Martin DD, Shephard MD, Freeman H, et al. Point-of-care testing of HbA1c and blood glucose in a remote Aboriginal Australian community. MJA. 2005;182:524-527. [pmid: 15896181].
29 Stratton IM, Adler AI, Neil AH, Matthews DR, Manley SE, Cull CA, Hadden D, Turner RC, Holman RR. on behalf of the UK Prospective Diabetes Study Group. Association of glycaemia with macrovascular and microvascular complications of type 2 diabetes (UKPDS 35): prospective observational study. BMJ. 2000;21:405-412. [pmid: 10938048].
30 Clark PM, Gray AM, Briggs A, Farmer AJ, Fenn P, Stevens RJ, Matthews DR, Stratton IM, Holman RR. on behalf of the UK Prospective Diabetes Study (UKPDS) Group. A model to estimate the lifetime health outcomes of patients with type 2 diabetes: the United Kingdom Prospective Diabetes Study (UKPDS) outcomes model (UKPDS no. 68).
31 The University of Oxford. UKPDS Outcomes Model. The Oxford Centre for Diabetes, Endocrinology & Metabolism. Available at: http://www.dtu.ox.ac.uk/outcomesmodel. Last accessed April 22, 2005.
32 Menzin J, Langley-Hawthorne C, Friedman M, et al. Potential short-term economic benefits of improved glycemic control: a managed care perspective. Diabetes Care. 2001;24(1):51-55. [pmid: 11194241].
33 Wagner EH, Sandhu N, Newton KM, et al. Effect of improved glycemic control on health care costs and utilization. JAMA. 2001;285(2):182-189. [pmid: 11176811].
34 Karter AJ, Ackerson LM, Darbinian JA, et al. Self-monitoring of blood glucose levels and glycemic control: the Northern California Kaiser Permanente Diabetes registry. American Journal of Medicine. 2001;111(1):1-9. [pmid: 11448654].
35 NCCLS. Evaluation of precision performance of clinical chemistry devices. Approved Guideline. NCCLS publication EP5-A. Villanova, PA. NCCLS. 1992.
36 Bland JM, Altman DD. Statistical methods for assessing agreement between two methods of clinical measurement. Lancet. 1986;i:307-101. [pmid: 2868172].