# PART II: Genetic tests in development for clinical use

## AIM

The aim of Part II of this project was to identify genetic tests currently in development for clinical cancer care. During this part of the project, one challenge was how to identify genetic tests “in development” that were pertinent to the purposes of this horizon scan. The methods section of this report details the systematic process that we developed and applied to the scientific and grey literature, in attempt to identify cancer genetic tests with more immediate clinical and commercial potential.

The final product of this part of the project is a database of genetic tests currently in clinical development for cancer care. These tests were identified during our search of the scientific and grey literature as well as through other additional resources such as expert interviews and scientific conferences. The focus of this database was to find genetic tests that are currently under investigation for clinical utility. By the time most medical tests in development reach testing for clinical utility, the new technology in development usually is associated with commercial interests. As a result, the focus of our search for genetic tests in development, centered around the LexisNexis^®^ database, which provides access to authoritative legal, news, public record, and business information via a set of searchable databases that contains over 36,000 sources of print media including newspapers, magazines, and legal documents.

## METHODS

Our approach to identify genetic cancer tests in this section can be divided into three separate processes:

1. searching the scientific literature
2. searching the grey literature
3. scientific meetings and expert interviews

We began with a search of the scientific literature. However, as we learned from our efforts during the Part I of this project, a systematic search of the scientific literature was not likely to be useful for the purposes of this horizon scan. As a result, the focus of our search for genetic tests in development centered on a systematic review of the grey literature and in particular, LexisNexis, as the source of information most applicable to our horizon scan project.

### 1 Scientific Literature search

A Medline search was conducted on July 12, 2005 to address the key question of identifying genetic tests in development for cancer. Briefly, we used search terms from 3 categories:

1. diagnostic test (ie. sensitivity and specificity, mass screening, diagnosis, predictive value, ROC curve, likelihood ratio)
2. gene or genetic or genomic test
3. top 10 cancers by mortality (lung, colon, breast, pancreas, prostate, leukemia, lymphoma, ovarian, esophagus, liver)*
  * top 10 cancers in estimated deaths based on data from American Cancer Society Surveillance Research, US Mortality Public Use Data Tapes, 1969-2002, and National Center for Health Statistics, CDC, 2004

The complete search strategy used is detailed in Appendix A4. The results of this initial exploratory search of the scientific literature was presented and discussed at an interim conference call with AHRQ. Based on a sampling of the abstracts from the Medline search, it was revealed that many of the studies identified, as potentially of interest, were preclinical exploratory reports of potential tumor biomarkers or genes/genomic arrays with possible associations with tumor diagnosis or activity. However, the chances that any of these early preclinical biomarker reports will eventually evolve into clinically validated and useful tests are slim.4 As a result, a significant majority of these reports would not be of interest or useful for the purposes of our particular horizon scan. Together with AHRQ, we thus decided to focus our energies towards searching grey literature sources.

### 2 Grey Literature search

As discussed earlier in Part I, in constructing our list of grey literature sources, we started with grey literature sources identified by the NLM’s Health Technology Assessment Information Resources.5 Furthermore, we supplemented this list of grey literature sources with additional databases through conversations with AHRQ (LexisNexis) and internal investigations (Google News, Early Research Detection Network, Cambridge HealthTech). By the end of this project, we identified 39 databases of interest. However, this list is not designed to be comprehensive. Below is a brief description of each grey literature source explored and the search strategies that we employed for each database.

For the purposes of this report, we have organized the grey literature sources that we examined into three categories:

#### Category I (High utility for the horizon scan)

##### a LexisNexis (http://www.lexisnexis.com)

LexisNexis provides access to authoritative legal, news, public record, and business information via a set of searchable databases that contains over 36,000 sources of print media including newspapers, magazines, and legal documents. Sources include public records, The New York Times, CNN, Bloomberg, Dun & Bradstreet, The Associated Press, Biotech Week, and NewsRx. This tool is the global legal and information division of Reed Elsevier.

We searched LexisNexis under the Medical News and Business News headings. Business News contained additional subheadings of interest: Industry News, Business and Finance, Mergers and Acquisitions, and Knight Ridder. For the purpose of our search, we began with the key terms “cancer” AND “test” covering a one year time period. We started with these terms to cast the widest net possible. However, if more than 1000 articles are returned for a search, LexisNexis does not provide individual title results. When this result occurred, we first altered the timeframe of our search and second, added an addition search term in order to be more specific in our request. If >1000 articles were returned for 6 months of records, our search terms were changed to “cancer” AND “gene” AND “test.” With either the two or three term combinations, we were able to generate a list of titles for a 1 year time period. (A time period of 1 year was chosen in the hope of capturing references to genetic tests that are more advanced in the clinical development process and perhaps more likely to be commercial available within a relatively short time. Therefore, by limiting our search to 1 year, we hoped to find genetic tests that might be relevant to CMS within the next 1-2 years, using the most efficient method possible.)

Two reviewers screened the list generated by the LexisNexis search for relevant titles. Complete articles were then retrieved for the titles identified as potentially applicable for our project. Articles were then read by two reviewers and a group decision was made regarding whether to include or exclude the test from our database. When a test was identified for inclusion, pertinent test information was extracted from the report and entered into the database. If additional data on a particular technology was needed, we often were able to extract missing information from the developer’s website.

##### b Cambridge Healthtech Institute (CHI) (http://www.healthtech.com/)

The Cambridge Healthtech Institute has developed and released the “CHI ToolBar.” The CHI Toolbar allows users to search eight different databases including the Biomedical NewsAnalyzer, which is a fully searchable, on-line database containing all press releases from many companies in the pharmaceutical, biotechnology, bioinformatics, diagnostics, medical device, equipment, drug delivery, contract research and manufacturing industries. Additionally, this tool provides access to the Biomedical Industry Analyzer, a directory of over 4600 companies in these sectors.

We searched the CHI database with the key terms “cancer,” “test,” and “gene.” These searches were limited to the field of oncology. We screened all of the titles that were obtained from these searches to identify reports of interest. Next, we retrieved and reviewed the full articles identified by our title screening and extracted pertinent information on potential genetic tests into our database.

#### Category II (Low to moderate utility for the horizon scan)

##### c Computer Retrieval of Information on Scientific Projects (CRISP) (http://crisp.cit.nih.gov/)

CRISP provides a listing of federally funded research projects conducted at universities, hospitals, and other research institutions in the biomedical fields. This database is maintained by the Office of Extramural Research at the National Institutes of Health and includes projects funded by the National Institutes of Health (NIH), Substance Abuse and Mental Health Services (SAMHSA), Health Resources and Services Administration (HRSA), Food and Drug Administration (FDA), Centers for Disease Control and Prevention (CDC), Agency for Health Care Research and Quality (AHRQ), and Office of Assistant Secretary of Health (OASH).

We searched CRISP using the combination of key terms “cancer” AND “test” AND “gene.” Two reviewers screened the titles for potential relevance and retrieved the complete reports for a sampling of projects. From the initial sampling of retrieved reports, it became evident that the CRISP database was limited to projects mainly investigating preclinical exploratory biomarkers or genomic arrays that might have an association with tumor diagnosis or activity. In this sense, CRISP provided information similar to a Medline search or other traditional scientific literature databases. Therefore, after consulting with AHRQ, we decided that CRISP would be less useful to our specific task of identifying genetic tests in development.

##### d Web of Knowledge (http://www.thomsonisi.com/)

ISI Web of Knowledge encompasses both multidisciplinary and specialized content as well as external collections, covering journals (including open access titles) books, proceedings, patents, chemical structures, evaluated Web content, grant funding, and preprints. All content in this database, including over 8,700 journals and 22 million patents, must meet editorial requirements to be included.

We searched Web of Knowledge using the key terms “cancer” AND “test” AND “gene” for a time period of one year. We screened a sampling of the titles that were obtained from these searches to identify reports of interest. We then retrieved the complete reports from a sampling of articles that represented promising leads for cancer genetic tests in development. From this sample of articles, it became evident that the Web of Knowledge is useful for identifying research of potential biomarkers that are mainly in the preclinical phase of development and far from establishing clinical utility or commercial development. In this respect, Web of Knowledge may be considered similar to Medline searches and therefore, it was decided that this resource would not be useful for our purposes and further exploration of Web of Knowledge was discontinued.

##### e Early Detection Research Network (EDRN) (http://www3.cancer.gov/prevention/cbrg/edrn/)

EDRN is a multi-disciplinary collaborative effort organized by the National Cancer Institute to identify and validate potential cancer biomarkers. EDRN focuses on speeding laboratory discoveries and their subsequent translation to clinical biomarkers. In addition, the goal of EDRN is to “provide timely, cost-effective clinical tests for early detection of cancer and identification of high-risk individuals.”6 This network is comprised of the following main components: 1) Biomarkers Developmental Laboratories, which develop and characterize new biomarkers or refine existing biomarkers; 2) Biomarkers Reference Laboratories, which serve as a resource for clinical and laboratory validation; 3) Clinical Epidemiology and Validation Centers, which conduct and support early phases of clinical and epidemiological research on the application of biomarkers; 4) a Data Management and Coordinating Center, which provides statistical, logistics, information support, and develops theoretical statistical approaches to pattern analysis of multiple markers simultaneously; and 5) an Informatics Center led by investigators at the National Aeronautics and Space Administrations Jet Propulsion Laboratory serving as the lead for the informatics component.

Since the goals of EDRN appeared to be similar to the goal of our horizon scan, we decided to search the most recent EDRN report (March 2005) to identify potential genetic biomarkers and tests that could be added to our database. In order to stay consistent with our justifications for discontinuing extensive explorations of databases such as Medline and Web of Knowledge, we only extracted biomarkers that had proceeded beyond the preclinical exploratory stage (phase one of development) and were at least being studied for clinical validity and utility (phase two and beyond). [Figure 1.]

Figure 1 Guiding Principles for Biomarker Research: Phases of Early Detection Research

* Figure 1 from National Cancer Institute, Division of Cancer Prevention. The Early Detection Research Network: Translational Research to Identify Early Cancer and Cancer Risk. Third Report. March 2005. p15

##### f National Research Register (NRR) (http://www.nrr.nhs.uk/search.htm)

The National Research Register is a database of ongoing and recently completed research projects funded by, or of interest to, the United Kingdom's National Health Service (NHS).

We searched The National Research Register using the combination of key terms “cancer,” “test,” and “gene.” We screened the titles to identify reports of interest. Next, we retrieved and reviewed the full articles that held potential for tests to be included in our database. However, the majority of potentially relevant articles, as hinted by their titles, referred to early preclinical, exploratory studies to identify potentially useful tests. As a result, we decided to discontinue further exploration of this resource.

##### g Canadian Institute of Scientific and Technical Information (CISTI) (http://cisti-icist.nrc-cnrc.gc.ca/main_e.html)

CISTI is a source for information in all areas of science, technology, engineering and medicine. CISTI began over 75 years ago as the library of the National Research Council of Canada and became the National Science Library in 1957. It contains over 50,000 different serial titles, over 600,000 books, conference proceedings and technical reports, and 2 million technical reports from around the world.

We searched Canadian Institute for Scientific and Technical Information using the combination of key terms “cancer” AND “test” AND “gene.” We screened all of the titles that were obtained from this search to identify reports of interest and pulled the full reports of articles that might fit our inclusion criteria above. Similar to NRR, the majority of titles screened in CISTI referred to phase I exploratory studies and were thus far from either commercial development or establishing clinical utility. We decided to discontinue further exploration of the CISTI database because of its limited utility to our horizon scan.

##### h Google (www.news.google.com)

Google News gathers stories from more than 4,500 news sources in English worldwide and automatically arranges them to present the most relevant news first. Results are compiled solely by computer algorithms, without human intervention, and include articles that have only appeared within the past 30 days.

We searched Google News using the key terms “cancer” AND “test” AND “gene.” We screened all of the titles that were obtained from this search for reports of interest. We then pulled the full articles of all titles of interest. Tests extracted from these articles of interest revealed significant overlap between Google and LexisNexis. In addition to this redundancy with LexisNexis, the Google search engine did not allow a search beyond 30 days. As a result of these limitations, we did not further explore Google for this horizon scan.

##### i Clinical Laboratory Improvement Amendments (CLIA) (http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfClia/Search.cfm)

CLIA regulates all laboratory testing (except research) performed on humans in the U.S. In total, CLIA covers approximately 175,000 laboratory entities. The Division of Laboratory Services, within the Survey and Certification Group, under the Center for Medicaid and State Operations has the responsibility for implementing the CLIA Program.

We searched CLIA using the simple search function with the key term “cancer.” We screened all of the titles that were obtained from this search and pulled the full reports of all articles that might fit our inclusion criteria above. Review of these articles and tests of interest, revealed that these sources focused mainly on genetic tests currently in use. Therefore, the CLIA database was probably more applicable and useful for Part I of this project.

##### j The Office of In Vitro Diagnostics Device Evaluation and Safety (OIVD) (http://www.fda.gov/cdrh/oivd/consumer-otcdatabase.html)

OIVD is part of the U.S. Food and Drug Administration's Center for Devices and Radiological Health. OIVD regulates all aspects of in-home and laboratory diagnostic tests (in vitro diagnostic devices or IVDs), helps new IVDs reach the medical marketplace, prevents the sale of unsafe or ineffective IVDs, and categorizes the complexity of IVDs according to the Clinical Laboratory Improvement Amendments of 1988 (CLIA '88), thereby defining the type of regulatory oversight applied to the product.

We searched OIVD with the key term “cancer.” We screened all of the titles that were obtained from this search and retrieved the full reports of all articles that had titles of interest. Review of these reports quickly revealed that all of the relevant reports in the OIVD database referred to tests already available for clinical use, thus making OIVD a resource more applicable for Part I of this project.

##### k FDA Pre-market Approval (http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMA/pma.cfm)

The Medical Device Amendments of 1976 to the Federal Food, Drug, and Cosmetic Act (the act) established three regulatory classes for medical devices. The amendments define a Class III device as one that supports or sustains human life or is of substantial importance in preventing impairment of human health or presents a potential, unreasonable risk of illness or injury. All devices placed into Class III are subject to premarket approval requirements. Pre-market approval by FDA is the required process of scientific review to ensure the safety and effectiveness of Class III devices.

We searched the Pre-market Approval Database with the key terms “cancer,” “test,” and “gene.” We screened all of the titles that were obtained from this search and retrieved the full reports of all articles of interest. Similar to OIVD, we found that the Pre-market Approval database identified tests already available for clinical use, thus making it a resource more applicable for Part I of this project.

##### l ClinicalTrials.gov (www.clinicaltrials.gov)

ClinicalTrials.gov provides regularly updated information about federally and privately supported clinical research in human volunteers. ClinicalTrials.gov gives you information about a trial's purpose, who may participate, locations, and phone numbers for more details.

We searched clinicaltrials.gov using the combination of key terms “cancer” AND “test” AND “gene.” We screened all of the titles that were obtained from this search strategy and retrieved the full reports of the titles of interest. Similar to databases like NRR and CISTI, most reports in ClinicalTrials.gov refer to genetic tests in preclinical phase I exploratory studies and could be considered too premature from either commercial development or establishing clinical utility. Therefore, we limited further exploration of ClinicalTrials.gov database due to its limited utility to our particular horizon scan.

##### m Online Computer Library Center (OCLC)’s FirstSearch (http://www.oclc.org/firstsearch/)

The OCLC FirstSearch database retrieves records from worldwide conferences, symposia, meetings, expositions, and congresses. This database covers a number of disciplines including the Arts, Humanities, Social Sciences, and Physical and Life Sciences.

Within the FirstSearch database, we searched PapersFirst from 2004-2005 using the key terms “cancer” AND “test” AND “gene.” We screened all of the titles that were obtained from this search but were unable to proceed further because the database did not allow access or retrieval of abstracts or full text reports.

##### n Health Technology Assessment Database (HTA) (http://www.york.ac.uk/inst/crd/htahp.htm)

The Health Technology Assessment (HTA) database contains information on healthcare technology assessments and is produced in collaboration with The International Network of Agencies for Health Technology Assessment (INAHTA) Secretariat, based in Sweden. The database contains records of ongoing projects being conducted by members of INAHTA as well as publications reporting completed technology assessments carried out by INAHTA members and other health technology assessment organizations.

We searched this database using the key terms: “cancer” AND “test” AND “gene.” We also applied the same search terms to the Data Abstracts of Reviews of Effects and Health Assessment Technology Database. As indicated by their titles, these technology assessments review analytical and clinical utility data on genetic tests already in use. Therefore, the HTA database would be more relevant for Part I of this project.

##### o NY Academy of Medicine (http://www.nyam.org/)

The Grey Literature Report is a quarterly publication of The New York Academy of Medicine Library alerting readers to new grey literature publications in public health as they are acquired. This report was first published in 1999 and acquires materials from various organizations publishing grey literature and gives them special cataloging treatment.

We searched the Grey Literature section of the Academy using the terms “cancer,” “test,” and “gene.” We screened all of the titles that were obtained from this search and retrieved the full reports of all articles of interest. A quick review of these titles and abstracts revealed that this database produced reports that were not specific to genetic tests in development. The few reports that did involve genetic testing usually contained clinical and analytical data for already established technologies.

##### p GreyLit Network (http://greylit.osti.gov/)

The GreyLIT Network is a portal for technical report information generated through federally funded research and development projects. It was developed by the Department of Energy's Office of Scientific and Technical Information (OSTI), in collaboration with the Department of Defense/ Defense Technical Information Center (DOD/DTIC), NASA, and the EPA. The GreyLIT Network was released in early response to recommendations from a May 2000 workshop on the concept of a “Future Information Infrastructure for the Physical Sciences” held at the National Academy of Sciences.

We searched the GreyLit Network with the combination of terms: “cancer,” “test” and “gene.” We screened all of the titles that were obtained from these searches and retrieved the full reports of a sampling of articles of interest. Abstracts from the GreyLit Network mainly referred to tests in a preclinical exploratory phase of development, similar to several databases mentioned earlier. As a result, we did not choose to explore this database in further detail for the purposes of this project.

##### q Health Services Research Projects in Progress (HSRProj) (http://www.academyhealth.org/hsrproj/search.htm)

HSRProj contains descriptions of research in progress funded by federal and private grants and contracts for use by policy makers, managers, clinicians and other decision makers. It provides access to information about health services research in progress before results are available in a published form.

We searched HSRProj with the terms “cancer,” “test,” and “gene.” We screened all of the titles that were obtained from this search and pulled the full reports of a sampling of articles that might fit our inclusion criteria above. The HSRProj database identifies research focused on health services research and not on test development. As a result, we limited our use of this resource for this horizon scan.

#### Category III (Not useful for the horizon scan)

##### r Other

We identified several additional grey literature tools available to explore. However, further investigation of these sources revealed that none of the resources would be useful for our horizon scan project. Table C lists these grey literature resources that we identified but did not use for any part of this project. Reasons for not using some of these resources include; they did not contain a search engine, were subscription services that we were unable to access, or were clearly oriented towards literature that was not applicable to our horizon scan on genetic testing in cancer.

### III Opinion leaders and scientific conferences

Interviews were conducted with different experts representing commercial laboratories, academic hospitals, and the FDA. Academic and government leaders were identified during our scientific and grey literature searches, including the EDRN network of principal investigators and consultants. Opinion leaders were affiliated with the University of Chicago, the FDA, Quest Diagnostics, and Roche Diagnostics. In addition, we attended two scientific meetings; (1) “Pharmacogenomics in Drug Development,” a workshop jointly sponsored by the Drug Information Association, FDA, Pharmacogenetic Working Group, PhRMA, and the Biotechnology Industry Organization, and (2) the 2005 American Society of Clinical Oncology (ASCO) Annual Meeting.

## RESULTS

### I Scientific Literature

Based on the search strategy detailed in Appendix A4, a total of 4492 citations were initially produced for cancer genetic tests in development as they applied to the top 10 cancers by mortality. Briefly, there were 4492 citations produced for the 10 cancers. In attempt to reduce this total, we limited the database timeframe to years 2000 to 2005, which resulted in 2519 citations for 3 of the top 10 cancers. Finally, we sampled citations for three of the cancers:

Using a broad definition for genetic tests “in development,” we sampled 3 cancers:

1. esophageal: 45/55 (81%) citations were screened in
2. pancreas: 77/110 (70%) citations were screened in
3. liver: 92/123 (75%) citations were screened in

Examples of abstracts screened in, include “development of a quantitative three-tiered algorithm and multi-gene RT-PCR to discriminate between Barrett’s esophagus and esophageal adenocarcinoma,” “chemokine receptor CXCR4 expression in colorectal cancer demonstrated significant associations with recurrence, survival and liver metastasis,” and “use of microsatellite marker of loss of heterozygosity and k-ras codon 12 mutation analysis of PCR in accurate diagnosis of pancreaticobiliary malignancy.”

Based on the sampling of the abstracts from the Medline search, we found that many of the papers were preclinical reports investigating different genes that may explain biological pathways of tumor development or reports of microarray investigations that are searching for genes of interest. Additionally, these reports of basic science and tumor cell are far from implementation and presentation as commercial projects. As a result, a significant majority of these papers would be excluded from our report.

### II Grey Literature

#### Category I High utility

##### LexisNexis and Cambridge Healthtech Institute

We comprehensively searched these databases using the methods described above. These databases had the highest yield in returning tests of interest.

###### A LexisNexis: Using the combination of key words “cancer,” “test,” and “gene,” we obtained the following results within the different subheadings of LexisNexis

1. Medical News (1 year) = 1132 citations
2. Business News/ Industry News (1 year) = 1241 citations
3. Business News/ Mergers and Acquisitions (1 year) = 233 citations
4. Business News/ Business and Finance (1 year) = 251 citations
5. Business News/ Knight Ridder (1 year) = 94 citations

Table A provides further detail of our search of LexisNexis. We scanned a total of 2951 titles from the combination of LexisNexis sources and identified 879 articles of interest. From the articles of interest, we extracted 142 tests of interest and ultimately 50 unique genetic tests. Database III provides a listing of the genetic tests that were obtained from the LexisNexis search.

###### B Cambridge HealthTech Institute

Table A also details our search strategy using the CHI Toolbar. Using the combination of “cancer,” “test,” and “gene,” we scanned a total of 494 titles and found 52 articles of interest. From these articles of interest, we identified 24 genetic tests of interest and 10 unique genetic tests.

Database III provides a listing of genetic tests in development for cancer as identified by both LexisNexis and CHI resources. Table 1 below demonstrates the distribution of cancer indications for all genetic tests found using LexisNexis and CHI databases. The ten most deadly cancers in the U.S. account for 80% (49 of 61) of the test indications, with breast cancer accounting for 20% (12 of 61) of these indications. The ‘other’ cancers being investigated include bladder, cervical, GIST, mesothelioma, and tumors of unknown origin. There were 17.6 tests of interest found for every 1000 titles scanned.

Table 1 Distribution of cancer targets for Category I genetic tests

Cancer | # of tests | % of total
Breast | 12 | 24%
Prostate | 10 | 15%
Lung | 10 | 15%
colorectal | 10 | 18%
pancreas | 0 | 0%
Ovarian | 4 | 6%
esophagus | 0 | 0%
liver | 1 | 1%
lymphoma | 0 | 0%
leukemia | 2 | 3%
Other | 12 | 19%
total indications | *61 | 100%

* total # of indications may be greater than total # of tests in the database because some tests may have multiple indications

Table 2 summarizes the distribution for test purpose among the genetic tests in found using LexisNexis and CHI. A significant majority (94%) of the investigations identified with LexisNexis and CHI were for disease diagnosis or management. Further information on test specifics was limited since clinical utility has yet to be established for most of these tests.

Table 2 Distribution of indicated use for Category I genetic tests

Use | # of tests | % of total
diagnosis/management | 52 | 95
primary prevention | 3 | 5
total tests | 55 | 100%

#### Category II Low to moderate utility

##### EDRN, CLIA, ClinicalTrials.gov, Google and others

Table B lists the category II grey literature resources investigated and summarizes the search strategies and results for each database. Initial literature searches of these databases found over 200,000 titles. However, after re-focusing our methods and discontinuing further exploration of low yield sources, we identified 190 abstracts of interest from 8 grey literature sources (Google, CISTI, CLIA, EDRN, FDA pre-market, ClinicalTrials.gov, and NY Academy of Medicine.) and found 39 unique genetic tests which are included in Database III.

The Early Detection Research Network publication identified 75 genetic tests in development; however, almost 80% (59 of 75) of these tests are in pre-clinical exploratory phase of drug development, while only 21% (16 of 75) are in at least phase 2 clinical validation studies. Only the latter tests, in at least phase 2 of clinical development studies, were included in Database III. Google News and clinicaltrials.gov also contributed to our category II grey literature database with 5 and 13 tests, respectively. The CLIA database identified 1 test in development that was of interest to our database while the FDA pre-market approval site identified 2 tests. The ten most deadly cancers in the U.S. account for 82% (40 of 49) of the total test indications; while ovarian cancer accounts for 22% (11 of 49) of these indications (Table 3 below). The ‘other’ cancers being investigated include bladder, cervical/ endometrial, kidney, and tumors of unknown origin.

Although it appears that almost all of the Category II genetic tests are associated with the diagnosis and management of cancer, it may be too premature to assign a definitive role for any of these tests since most are only in pre-clinical phase of development and have yet to establish any clinical validity or utility data.

Table 3 Distribution of cancer indication among Category II genetic tests

Cancer | # of tests | % of total
Breast | 7 | 14%
prostate | 7 | 14%
Lung | 5 | 10%
colorectal | 8 | 16%
pancreas | 0 | 0%
ovarian | 11 | 22%
esophagus | 0 | 0%
liver | 1 | 2%
lymphoma | 0 | 0%
leukemia | 1 | 2%
Other | 9 | 18%
total indications | 49 | 100%

* total # of indications may be greater than total # of tests in the database because some tests may have multiple indications

#### Category III Not applicable

These resources did not yield any search results because they were either nonoperational websites or contained information not applicable to this particular report.

### III Interviews, conferences

#### A Interviews

We conducted interviews with different experts representing commercial laboratories, academic hospitals, and the FDA.

1. Olufunmilayo Olopade, MD, Director of Cancer Risk Clinic, Univ. of Chicago
2. Steve Gutman, PhD, Director of OIVD, FDA
3. Richard Bender, MD, Medical Director, Quest Diagnostics
4. Gerd Moss, MD, Austin Finley, PhD, John Rich, Roche Diagnostics

During these interviews, we discussed issues concerning current genetic tests available (Part I), as well as tests in clinical development (Part II). Drs. Olopade and Gutman both reviewed draft versions of our current genetic test database from Part 1. Meanwhile, Dr. Bender from Quest Diagnostics suggested looking at the commercial websites for information on current genetic tests.

Dr. Olopade is a member of the EDRN Network Consulting Team and she is the Director of the Cancer Risk Clinic at the University of Chicago. During our interview with Dr. Olopade, we discussed a wide range of issues involved with genetic testing. Particular tests discussed were Oncotype Dx, Mammaprint, OvaChek, BRCA1 and 2, and Her2-neu. Additional topics mentioned included: the impact of Myriad’s Genetic direct-to-consumer marketing campaign for its BRCA testing for breast cancer screening, direct-to-consumer genetic test companies such as DNA Direct, Genetests.org as a source for genetic tests research, and the future of pre-implantation genetic testing. Finally, Dr. Olopade also mentioned a new pharmacogenomic test in development, involving gene polymorphisms for metabolizing CPT-11 (Camptosar, irinotecan) chemotherapy used in advanced colon cancer.

Dr. Bender is the Medical Director for Hematology/Oncology at Quest Diagnostics. We spoke with Dr. Bender at the ASCO Annual Meeting where we discussed issues involving genetic testing from a commercial laboratory standpoint. In particular, we discussed future pharmacogenomic testing and some of the challenges in validating these new tests. Dr. Bender introduced an upcoming 7-gene pharmacogenomic panel for evaluating response in chemotherapy for colon cancer. More specifically, this pharmacogenomic panel looks for several gene polymorphisms (ERCC1, UGT1A1, TS, XPD, GST-P1, XRCC1, and DPD) in order to evaluate the likelihood of toxicity and/or response to 5FU, oxaliplatin and irinotecan chemotherapy.

Dr. Gutman is Director of OIVD at the FDA. Due to confidentiality reasons, Dr. Gutman was not allowed to speak about specifics of individual genetic tests available or in development. However, he did discuss pertinent issues such as “home brew” vs. FDA approval, direct-to-consumer genetic test companies such as DNA Direct, the future of genomic testing, and co-development of drug and diagnostic test. Dr. Gutman also received a preliminary draft of the genetic test database for review.

We held a conference call with representatives from Roche Diagnostics to discuss current and future genetic tests in cancer. Involved in the call were the head of oncology test development (Moss), director of sales and reimbursement (Rich), and the director of public policy (Finley). Roche Diagnostics is currently testing their AmpliChip technology in large multi-center international clinical trials for leukemia patients. Roche’s aim is to develop their Amplichip technology for use in leukemia patients, in clinical trials to help classify leukemia patients and correlate to outcomes. Genetic tests for cancer using Roche’s Amplichip technology, as well as other cancer genetic tests in development identified by expert review of this report by Roche, have been included in Database III.

#### B Conferences

##### 1 Pharmacogenomics in Drug Development and Regulatory Decision Making

This meeting was jointly sponsored by the Drug Information Association, FDA, Pharmacogenetic Working Group, PhRMA, and the Biotechnology Industry Organization. The focus of this workshop was on the implementation and integration of pharmacogenomics in the mid to late clinical phases of the development of new drugs, biologics, and associated devices. A draft version of the FDA’s “Drug-Diagnostic Co- Development Concept Paper” was provided for discussion.

##### 2 The 2005 American Society of Clinical Oncology (ASCO) Annual Meeting

Numerous opportunities to gather information about genetic testing were available at the ASCO Annual Meeting. With the recent design, development, and clinical evaluation of several new targeted agents in oncology, more specific tests are needed to select the patients most appropriate for these agents and to evaluate their response to these molecularly targeted therapies.

From a scientific standpoint, the ASCO meeting featured many important studies and abstracts in which the integration of diagnostic tests with specific and targeted types of therapies was the focus of the presentation. Among the tests presented included: BRCA1 and pancreatic cancer risk, circulating tumor cell assay for breast cancer, EGFR expression in colon cancer and response to cetuximab, BCR/abl mutations and imatinib (Gleevec) resistance, and pharmacogenetic studies for 5-FU based chemotherapy regimens. In addition to abstracts, the ASCO meeting also featured several presentations relevant to our project as part of their cancer genetics track. Examples of presentation titles include, “Beyond anatomic staging: is it time to take the leap into the molecular era?” and “Clinical relevance of genetics and genomics in gastrointestinal cancer: current and future biologic paradigms.”

The ASCO meeting also provided excellent opportunity to make contacts with several of the commercial vendors involved in genetic testing for cancer. In particular, the meeting featured over 400 corporate exhibits where attendees could visit booths, speak with representatives from the various pharmaceutical, medical diagnostic, and commercial laboratories, and obtain clinical and commercial literature regarding specific tests. There were numerous companies involved in genetic testing for cancer present at the corporate exhibitor hall, such as Quest Diagnostics, LabCorp, Genomic Health, US Labs, Roche Diagnostics, and Veridex.

## Summary

Our initial exploration of the scientific literature led to our realization that Medline searches would be more useful for collecting information of various biomarker and genetic tests in the pre-clinical stage of development. We concluded that for the purposes of this report, a different search strategy would have to be employed in order to more efficiently identify genetic tests in later phases of development that may have clinical impact in the very near future. As a result, we focused our search to the grey literature and were able to identify 104 genetic tests in development. Among these 104 tests, over two-thirds (60 of 104, 68%) were identified from the LexisNexis (n=50) and Cambridge Healthtech Institute (n=10) databases. Another 39 tests (38%) in development were found among 8 additional grey literature databases. The remaining 5 tests (4%) were added through additional alternative resources such as interviews with opinion leaders and attendance at national conferences. Three-quarters of the tests (84 of 104, 76%) were being developed for only five of the top 10 most common cancers by mortality. Breast, prostate, lung, colorectal, and ovarian accounted for these 5 most common indications. Finally, although it appears that almost all of these genetic tests in development are associated with the diagnosis and management of cancer, it would be speculative to assign a more definitive role for most of these tests since clinical validity or utility has yet to be established.