# Sample titles from searches of the grey literature databases

## a LexisNexis

“Collaboration to focus on the role of DNA in colon cancer detection”

“Tm Bioscience to manufacture novel breast cancer risk testing reagents for Intergenetics”

“Matritech says study data show its bladder-cancer test is cost-effective”

## b Cambridge Healthtech Institute (CHI)

“Abbott Data Published in Nature Reveals A Promising New Approach to Cancer”

“ACADIA Pharmaceuticals Expands Technology Platform to Target Tyrosine Kinase Linked Receptors”

“Broad Institute to Conduct Large-Scale Genotyping Project Using Affymetrix Technology.”

## c Computer Retrieval of Information on Scientific Projects (CRISP)

“Genetic Abnormalities Early on the Path of Breast Cancer”

“CYP1A1 and CYP1B1 genes in race-related Prostate Cancer”

“LEF/TCF Expression in Colon Cancer”

## d Web of Knowledge

“Induction of Th1-type immunity and tumor protection with a prostate-specific antigen DNA vaccine”

“Pituitary tumor transforming gene (PTTG) induces genetic instability in thyroid cells”

“Novel mechanism of inhibition of nuclear factor-kappa B DNA-binding activity by diterpenoids isolated from Isodon rubescens”

## e Early Detection Research Network (EDRN)

## f National Research Register (NRR)

“Analysis of BRCA1 gene mutations in familial and early onset breast cancer”

“An investigation of susceptibility genes for prostate cancer”

“Analysis of expression of RNA profiles in primary breast cancer”

## g Canadian Institute of Scientific and Technical Information (CISTI)

“Detection of Metastatic Potential in Breast Cancer by Rho-GTPase and WISP3 Proteins”

“Identification of HP1 Target Genes Involved in Progression of Breast Cancer”

“Investigation of Alpha6 Integrins and Their Signaling Intermediates as Prognostic Markers for Breast Cancer”

## h Google

“New Test Predicts Breast Cancer Risk”

“New Gene Chip may be Cancer Diagnostic Tool”

“Silenced Gene Suggests Greater Risk, Possible Marker For African-Americans With Prostate Cancer”

## i Clinical Laboratory Improvement Amendments (CLIA)

“Abbott Architect I2000 system (Fujirebio Diagnostics Inc, Architect CA 15-3 reagent kit)”

“Asymmetrx prostate-63 cancer diagnostic reagent”

“TOSOH AIA-360 (ST AIA Pack 27.29)”

## j The Office of In Vitro Diagnostics Device Evaluation and Safety (OIVD)

“Dakocytomation HER2 FISH PharmDx Kit”

“Urovysion bladder cancer kit”

“Architect CA 15-3 assay”

## k FDA Pre-market Approval

“immunochemistry analyzer”

“prostate specific antigen (PSA) for detection and management of prostate cancers”

“digital mammographic x-ray system”

## l ClinicalTrials.gov

“Microarray Analysis for Human Genetic Disease”

“Genetic and Environmental Risk Assessment for Colorectal Cancer in Healthy Participants”

“Microsatellite Analysis of Urinary Sediment in Detecting Bladder Cancer”

## m Online Computer Library Center (OCLC)’s FirstSearch

“Novel Pentablock Copolymers as Non-Viral Vectors for Gene Therapy against Cancer”

“451-034: Fuzzy Neural Network Applications for Gene Selection and Cancer Classification”

“APC, K-ras, and p53 Gene Mutations in Colorectal Cancer Patients: Correlation to Clinicopathologic Features and Postoperative Surveillance”

## n Health Technology Assessment Database (HTA)

“Screening for ovarian cancer: a systematic review”

“Genetic diagnosis by PCR,” and “Colorectal cancer screening.”

## o NY Academy of Medicine

“Community health profiles: the health of Southwest Brooklyn”

“FDA hinders cancer vaccines”

“Fulfilling the potential of cancer prevention and early detection: an American Cancer Society and Institute of Medicine Symposium”

## p GreyLit Network

“Cancer risk assessment: Should new science be applied? A workgroup summary”

“Targeting human breast cancer cells that overexpress HER-2/neu mRNA by an antisense iron responsive element”

"Investigation of the candidate tumor suppressor gene PRK in prostate cancer”

## q Health Services Research Projects in Progress (HSRProj)

“Improving palliative care in chronic critical illness”

“Mammography disparities in elderly African American women”

“Socio-ecological variables/cancer screening behaviors”