# Exploratory Medline search strategy: genetic tests for 10 cancers

Ovid MEDLINE(R) 1966 to June Week 5 2005

# | Search History | Results
1 | exp "sensitivity and specificity"/ | 182609
2 | exp Predictive Value of Tests/ | 61018
3 | exp ROC CURVE/ | 7998
4 | exp Mass Screening/ | 69062
5 | exp diagnosis/ | 3543147
6 | exp REPRODUCIBILITY OF RESULTS/ | 106784
7 | exp false negative reactions/ or false positive reactions/ | 24280
8 | predictive value.tw. | 26661
9 | (sensitivity or specificity).tw. | 386606
10 | accuracy.tw. | 90063
11 | screening.tw. | 150990
12 | roc.tw. | 5785
13 | reproducibility.tw. | 23848
14 | (false positive or false negative).tw. | 27567
15 | likelihood ratio.tw. | 2116
16 | or/1–15 | 3980953
17 | exp genetic screening/ | 12094
18 | ((gene or genes or genetic$) and (diagno$ or test$ or screen$)).tw. | 169073
19 | or/17–18 | 174880
20 | exp cell culture techniques/ | 11135
21 | exp cell line/ | 355216
22 | In Vitro/ | 330724
23 | exp biological assay/ | 24262
24 | exp tumor stem cell assay | 3161
25 | or/20–24 | 707287
26 | (16 and 19) not 25 | 70418
27 | limit 26 to humans | 16623
28 | 26 not 27 | 53795
29 | limit 28 to english language | 48399
30 | limit 29 to (addresses or bibliography or biography or case reports or congresses or consensus development conference or consensus development conference, nih or dictionary or directory or editorial or festschrift or government publications or guideline or interview or lectures or legal cases or legislation or letter or meta analysis or news or newspaper article or patient education handout or periodical index or practice guideline or "review" or review, academic or "review literature" or review, multicase or "review of reported cases" or review, tutorial) | 12504
31 | 29 not 30 | 35895
32 | exp prostate neoplasms/ | 46076
33 | 31 and 32 | 352
34 | limit 33 to yr=” 2000–2005” | 255
35 | exp ovarian neoplasms/ | 39000
36 | 31 and 35 | 573
37 | limit 36 to yr=” 2000–2005” | 354
38 | exp colonic neoplasms/ | 45633
39 | 31 and 38 | 361
40 | limit 39 to yr=” 2000–2005” | 164
41 | exp lung neoplasms/ | 101151
42 | 31 and 41 | 428
43 | limit 42 to yr=” 2000–2005 | 258
44 | exp leukemia/ | 141459
45 | 31 and 44 | 922
46 | limit 45 to yr=” 2000–2005 | 400
47 | exp lymphoma, non-hodgkin/ | 53794
48 | 31 and 47 | 491
49 | limit 48 to yr=” 2000–2005” | 256
50 | exp breast neoplasms/ | 122806
51 | 31 and 50 | 1501
52 | limit 51 to yr=” 2000–2005” | 902
53 | exp esophageal neoplasms/ | 22840
54 | 31 and 32 | 88
55 | limit 33 to yr="2000 – 2005" | 52
56 | exp liver neoplasms/ | 79138
57 | 31 and 35 | 210
58 | limit 36 to yr="2000 – 2005" | 123
59 | exp pancreatic neoplasms/ | 31833
60 | 31 and 38 | 171
61 | limit 39 to yr="2000 – 2005" | 110
62 | 33 or 36 or 39 or 42 or 45 or 48 or 51 or 54 or 57 or 60 | 4492
63 | 34 or 37 or 40 or 43 or 46 or 49 or 52 or 55 or 58 or 61 | 2519