# Additional companies and websites

Abbot | http://www.abbottdiagnostics.com/
Adnagen | http://www.adnagen.com/
Agendia | http://www.agendia.com/
AMDL | http://www.amdl.com/
Applied Imaging Corp | http://www.aicorp.com/
AstraZeneca | http://www.astrazeneca.com/
BioCurex | http://www.biocurex.com/
Cangene Biotech | http://www.cangene.com/
CeMines | http://www.cemines.com/
ChondroGene | http://www.chondrogene.com/
Ciphergen Biosystems | http://www.ciphergen.com/
Corixa | http://www.corixa.com/
Correlogic | http://www.correlogic.com/
Cytogen | http://www.cytogen.com/
DakoCytomation | http://www.dako.com/
Diagene | http://www.diagene.com/
DiagnoCure | http://www.diagnocure.com/
Epigenomics | http://www.epigenomics.com/
Exagen | http://www.exagendiagnostics.com/
Fujirebio Diagnostics | http://www.fdi.com/
GenoID | http://genoid.net/eng/welcome.html
Genomic health | http://www.genomichealth.com/
Gen-Probe | http://www.gen-probe.com/
Genzyme | http://www.genzyme.com/
GMP Companies | http://www.gmpcompanies.com/
Health discovery Corporation | http://www.healthdiscoverycorp.com/
Healthtronics | http://www.healthtronics.com/
IMI Medical | http://www.imimedical.com/
Immunicon | http://www.immunicon.com/
Intergenetics | http://www.intergenetics.com/
LabCorp | http://www.labcorp.com/
Matritech Inc. | http://www.matritech.com/
Medicorp | http://www.medicorp.com/
Metagenex | http://www.metagenex.fr/
Methexis | http://www.methexis-genomics.com/
Microprevention Tests no website found Myriad Genetics | http://www.myriad.com/
Orion Genomics | http://www.oriongenomics.com/
Power3 | http://www.power3medical.com/
Procyon | http://www.procyonbiopharma.com/
Qualigen | http://www.qualigeninc.com/
Quest diagnostics | http://www.questdiagnostics.com/
Roche | http://www.roche-diagnostics.com/
Sequenom | http://www.sequenom.com/
Specialty Laboratories | http://www.specialtylabs.com/
Tessera | http://www.tesserainc.com/
Tm Bioscience | http://www.tmbioscience.com/
Tripath Imaging | http://www.tripathimaging.com/
US LABS | http://www.uslabs.net/
Veridex | http://www.veridex.com/
ViroLogic | http://www.monogrambio.com/
Vitatex | http://www.vitatex.com/
Wako | http://www.wakousa.com/