# Synopsis of select commercial diagnostic laboratories (information from company websites)

## Quest Diagnostics (Teterboro, NJ) www.questdiagnostics.com

Quest Diagnostics is the nation's leading provider of diagnostic testing, information and services. The information we provide to health care practitioners and consumers enables them to make better decisions and improve care. With $4.7 billion in annual revenues, Quest Diagnostics offers the broadest access to clinical testing services through its national network of 30-plus regional laboratories, approximately 155 rapid response laboratories and almost 2,000 patient service centers. Quest Diagnostics is the leading provider of specialty testing, including gene-based testing, and is the leader in routine medical testing, drugs of abuse testing, and anatomic pathology testing. Through partnerships with pharmaceutical, biotechnology and information technology companies, Quest Diagnostics provides support to help speed the development of health care insights and new therapeutics.

## Laboratory Corporation of America^®^, LabCorp^®^ (Burlington, NC) www.labcorp.com

LabCorp is a pioneer in genomic testing and the commercialization of new diagnostic technologies. LabCorp is one of the world's largest clinical laboratories, with annual revenues of $3.1 billion in 2004. Headquartered in Burlington, North Carolina, LabCorp has more than 23,500 employees and offers more than 4,400 clinical tests ranging from routine blood analyses to the most sophisticated molecular diagnostics. LabCorp tests more than 340,000 specimens daily for over 220,000 clients nationwide.

## Specialty Laboratories (Valencia, CA) www.specialtylabs.com

Specialty Laboratories is a leading hospital-focused clinical reference laboratory, performs highly advanced, clinically useful testing services for hospitals, laboratories and physician specialist communities nationwide. With an extensive menu of clinical tests for the diagnosis and treatment-management of disease, Specialty offers clients a singlesource solution for their esoteric testing needs. Specialty also supports its test offering with distinguished R&D capabilities. Through internal research programs and technology partnerships, Specialty develops new and enhanced clinical tests for reliable and costeffective patient assessment