# Glossary of acronyms used

## Tests

EIA: Enzyme immunoassay
FISH: Fluorescence in-situ hybridization
ICC: Immunocytochemistry
ICMA: Immunochemiluminometric assay
IHC: Immunohistochemistry
IRMA: Immunoradiometric assay
MEIA: Microparticle enzyme immunoassay
PCR: Polymerase chain reaction
RIA: Radioimmunoassay
RT-PCR: Reverse transcriptase polymerase chain reaction

## Diseases

ALL: Acute lymphocytic leukemia
AML: Acute myelogenous leukemia
APL: Acute promyelocytic leukemia
CLL: Chronic lymphocytic leukemia
CML: Chronic myelogenous leukemia
CTCL: Cutaneous T-cell lymphoma
FAP: Familial adenomatous polyposis
HNPCC: Hereditary non-polyposis colon cancer
MM: Multiple myeloma
NHL: Non-Hodgkin's lymphoma
PNH: Paroxysmal nocturnal hemoglobinuria