# Tables

Table A Search strategy and results for Category I grey literature resources

Search Tool | Date | Timeframe | Search | Notes | Hits | Reports of Interest | Tests of Interest
LexisNexis (http://www.lexisnexis.com/) | 7/8/05 | 6 months | gene! or geno! and test! and cancer! | Medical News | >1000
| 7/8/05 | 1 year | gene! or geno! and test! and cancer! | Medical News | >1000
| 7/18/05 | 1 year | Cancer and gene and test | Medical News | 1132 | 586 | 17
| 7/19/05 | 1 year | Cancer and test | Business News/ Industry News | 1241 | 147 | 61
| 7/19/05 | 1 year | Cancer and test | Business news/ Mergers and Acquisition | 233 | 38 | 22
| 7/19/05 | 1 year | Cancer and test | Business news/ Business and Finance | 251 | 102 | 41
| 7/19/05 | 1 year | Cancer and test | Business news/ Knight Ridder | 94 | 6 | 1
Cambridge Health Tech Institute (CHI) (http://www.healthtech.com/) | 7/26/05 | 3 months | Cancer | limit to oncology | 466 | 36 | 13
| 7/11/05 | 3 months | Cancer, test | limit to oncology | 26 | 14 | 9
| 7/11/05 | 3 months | Cancer, test, gene | limit to oncology | 2 | 2 | 2

Table B Search strategy and results for Category II grey literature resources

Search Tool | Date | Timeframe | Search terms | Notes | Hits | Reports of interest | Tests of interest
Google (www.news.google.com) | 7/14/05 | past 30 days | Cancer | | 59,200
| 7/14/05 | past 30 days | Cancer, test | | 4,010
| 7/14/05 | past 30 days | Cancer, test, gene | | 267 | 7 | 5
Canadian Institute of Scientific and Technical Information (CISTI) (http://cisti-icist.nrc-cnrc.gc.ca/main_e.html) | 7/14/05 | 2004–2005 | Cancer | | 14,780
| 7/14/05 | 2004–2005 | Cancer, test | | 977
| 7/14/05 | 2004–2005 | Cancer, test, gene | | 255 | 8 | 0
Clinical Laboratory Improvement Amendments (CLIA) (http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfClia/Search.cfm) | 7/11/05 | Since 2000 | Cancer | Simple search | 63 | 1 | 1
| 7/11/05 | Since 2000 | Cancer, test | Simple search | 0
Office of In Vitro Diagnostics (OIVD) (http://www.fda.gov/cdrh/oivd/consumer-otcdatabase.html) | 7/11/05 | | Cancer | Captures tests already available (Part I) | 69 | 0 | 0
| 7/11/05 | | Cancer, test | | 16 | 0 | 0
| 7/11/05 | | Cancer, test, gene | | 2 | 0 | 0
FDA pre-market approval (http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMA/pma.cfm) | 7/11/05 | | Cancer | Simple search | 124 | 2 | 2
| 7/11/05 | | Cancer, test | Simple search | 32 | 0 | 0
| 7/11/05 | | Cancer, test, gene | Simple search | 0
Early Detection Research Network (EDRN) (http://www3.cancer.gov/prevention/cbrg/edrn/) | March 2005 | | Biomarkers, Phase II or greater developmental status | Summary tables by organ site from the Third Report, March 2005 | | 75 | 14
ClinicalTrials.gov (http://www.clinicaltrials.gov) | 7/12/05 | | Cancer | | 2588 | *
| 7/12/05 | | Cancer, test | | 347 | 43 | 11
| 7/12/05 | | Cancer, test, gene | | 57 | 0 | 0
Computer Retrieval of Information on Scientific Projects (CRISP) (http://crisp.cit.nih.gov/) | 7/13/05 | From 1972 | Cancer | | 10,582 | *
| 7/13/05 | From 1972 | Cancer, test | | 2661 | *
| 7/15/05 | From 1972 | Cancer, test, genetic | | 969 | 165 | *
National Research Register (NRR) (http://www.nrr.nhs.uk/search.htm) | 7/11/05 | | Cancer | | 20,835 | *
| 7/11/05 | | Cancer, test | | 1212 | *
| 7/11/05 | | Cancer, test, gene | | 79 | 0 | 0
FirstSearch (OCLC) (http://www.oclc.org/firstsearch/) | 7/26/05 | 2004–2005 | Cancer | PaperFirst- titles only | 47,181 | *
| 7/26/05 | 2004–2005 | Cancer, test | | 141 | *
| 7/26/05 | 2004–2005 | Cancer, test, gene | | 1 | 0 | 0
ISI Web of Knowledge (http://www.thomsonisi.com/) | 7/18/05 | year to date | Cancer | Cross Search searches patents and scientific abstracts | 96,230 | *
| 7/18/05 | year to date | Cancer, test | | 3751 | *
| 7/18/05 | year to date | Cancer, test, gene | | 610 | *
Health Technology Assessment (http://www.york.ac.uk/inst/crd/htahp.htm) | 7/11/05 | | Cancer, test, genetic | no limits. TA contain clinical data | 745 | *
| | | Cancer, test, genetic | Data Abstracts of Reviews of Effects and Health Assessment Technology Database | 213 | *
NY Academy of Medicine (http://www.nyam.org/) | 7/11/05 | | Cancer | keyword limited to Gray Literature | 135 | 1 | 0
| 7/11/05 | | Cancer, test | | 3 | 0 | 0
| 7/11/05 | | Cancer, test, gene | | 0 | 0 | 0
GrayLit Network (http://graylit.osti.gov/) | 7/11/05 | | Cancer | Limit to DTIC and DOE databases | 200 | *
| 7/26/05 | | Cancer, test | Limit to DTIC and DOE databases | 7 | 1 | 0
| 7/11/05 | | Cancer, test, gene | Limit to DTIC and DOE databases | 248 | *
Health Services Research Projects in Progress (HSRProj) (http://www.academyhealth.org/hsrproj/search.htm) | 7/11/05 | | Cancer | | 494 | *
| 7/11/05 | | Cancer, test | | 115 | 0 | 0
| 7/11/05 | | Cancer, test, gene | | 0 | 0 | 0

* Further data extraction was discontinued (see Methods for detailed explanation for each individual resource)

Table C Category III grey literature resources

Search Tool | Description | Notes
National Guidelines Clearinghouse (www.guideline.gov) | A public resource for evidence-based clinical practice guidelines | Guidelines are formed from clinical and analytical utility data. Tests that are in development do not yet have this data available
Networked Digital Library of Theses (http://www.ndltd.org/index.en.html) | Organization dedicated dissemination and preservation of electronic analogues to the traditional paper-based theses and dissertations | Theses are preliminary reports from academic research programs. The majority are not commercially active and those that are will be seen in other reports
System for Information on Grey Literature in Europe (SIGLE) (http://www.york.ac.uk/services/library/guides/sigle.htm) | Computerized index to reports and other grey literature produced in Europe | Grey Literature search tool that requires a subscription
TheseNet (http://www.sudoc.abes.fr/) | French Theses collection. Now called Systeme Universitaire de Documentation. | Non-English.
AMICUS (National Library of Canada) (http://amicus.collectionscanada.ca/aaweb/aalogine.htm) | Canadian national library catalogue | Library holdings overlap significantly with Medline and reports contained therein are based on clinical and analytical data
Australian National Library Catalog (http://catalogue.nla.gov.au/) | Australian national library catalogue | Library holdings overlap significantly with Medline and reports contained therein are based on clinical and analytical data
CABOT (Canadian Research Database) (http://cahspr.ca/cabot/) | Canadian research database. | This website had a nonfunctional search tool.
British Library (http://www.bl.uk/) | British library catalogue | Library holdings overlap significantly with Medline. Similar to searching NLM
FDA OIVD new products (http://www.fda.gov/cdrh/oivd/consumer-otcdatabase.html) | New OIVD products as of 7/1/05 | Web site still under construction
National Library of Medicine's LocatorPlus (http://locatorplus.gov/) | Search for book, journal and audiovisual titles in the NLM collections | Searches NLM. This source will return a similar dataset to other library holdings
Database of Abstracts of Reviews of Effects (DARE) (http://www.york.ac.uk/inst/crd/darehp.htm) | Structured abstracts of quality-assessed reviews | Included in HTA database search above
CMA Infobase (http://mdm.ca/cpgsnew/cpgs/index.asp) | Canadian Clinical Practice Guidelines. | Guidelines are formed from clinical and analytical utility data. Tests that are in development do not yet have this data available
BIREME Databases (http://www.bireme.br/bvs/bireme/I/homepage.htm) | Scientific and technical health information with the countries and among the countries of the Latin America and the Caribbean region | We are only interested in Health Sciences Section. The search tools used are Medline and LILACS.
Search Adobe PDF Online (http://www.searchpdf.adobe.com) | Searches PDF files on line | Nonfunctional search tool
DIMDI databases (http://www.dimdi.de/static/en/db/recherche.htm) | German Institute of Medical documentation and information. | Not In English and uses Medline
DIRLINE (http://dirline.nlm.nih.gov/) | Directory of Health Organizations Online. | Not applicable to our report. Organized by National Library of Medicine
Directory of Database of Research (JAPAN) (http://read.jst.go.jp/EN/) | Listing of research taking place in Japan. | Reports similar to those of Medline
Dissertation Abstracts (http://library.dialog.com/bluesheets/html/bl0035.html) | Subject, title, and author guide to virtually every American dissertation accepted at an accredited institution since 1861. | Dissertations are preliminary reports from academic research programs. Utility of dissertations for purposes of this report is unclear.
ERIC database (http://www.eric.ed.gov/) | Education literature. | Not applicable to our report
DrugResearcher.com (http://www.drugresearcher.com/) | Drug development in Europe. | This site is not directed towards biomarker development and thus is not applicable to our report.
ThePinkSheet.com (http://www.thepinksheet.com) | Prescription pharmaceuticals and biotechnology information. | A subscription is needed for information beyond the title
Reuters Health (www.reutershealth.com) | Supplier of health and medical news on the Internet | A subscription is needed for information beyond the title