# Genetic tests in development

Name | Other name | Use | breast | prostate | lung | colorectal | pancreas | ovarian | esophogus | liver | lymphoma | leukemia | other
AFP-L3 | | primary prevention | | | | | | | | X
alpha Catenin | methylation marker | prognosis | X
APC | | detection | | | | X
BAT-26 | microsatallite instability | detection | | | | X
bladder cancer test | | diagnosis | | | | | | | | | | | X
BladderChek | NMP22 | diagnosis | | | | | | | | | | | X
Breast Cancer Detection | Nipple Aspirate Fluid | diagnosis | X
Breast Cancer Outcome Prediction Test | PIX2/TTF1 | diagnosis | X
Cancer antigen 72-4 | CA 72-4 | diagnosis | | | | | | | | | | | X
CDK family | cyclin dependent kinase family | management | | | X
CDKN24 | methylation marker | detection | | | | X
CDP/Cux | | diagnosis | X
CellSearch | circulating tumor cells | diagnosis | X
CeMines CellCorrect Lab | | diagnosis | | | X
chromosome 8q gain | | management | | | | | | X
c-Kit pharmDx | Gleevec sensitivity test | management | | | | | | | | | | | X
colorectal cancer test | | diagnosis | | | | X
colorectal gene panel | 7 gene pharmacogenomic panel | management | | | | X
Colorectalert | | diagnosis | | | | X
Conversion Analysis | Conversion Technology | diagnosis | | | | X
Cox-2 RNA | stool | detection | | | | X
cPSA | complexed PSA | management | | X
CupPrint | | management | | | | | | | | | | | X
Cyfra 21-1 | cytokeratin fragment 19 | diagnosis | | | X
Cytokeratin 20 | CK 20 | diagnosis | | | | X
CytoVision | | diagnosis | | | | | | | | | | X
des-gamma carboxyprothrombin | | detection | | | | | | | | X
DNA methylation | Oncomethylome | detection | | X | X | | | X | | | | | X
DNA methylation | Second Code | diagnosis | | X | X | X
EEF1A2 | elongation factor | management | X
EGFR | Genzyme | detection | | | X | | | X | | | | | X
EGFR | | management | | | X
EPCA | | diagnosis | | X
eTag | | management | X | | X
Genomic Test | 3q, 7q, 16q, 17pter-q21 | diagnosis | | | | | | X
GOS | stool | detection | | | | X
GSTM1 | | prediction | | | X
GSTP1 | | management | | X
Her-1, Her-2, Her-3, Her-4 | | diagnosis | X
HLA-E | | prognosis | | | | | | | | | | | X
HP1alpha | | management | X
HPV test | DNA with Pap Test | diagnosis | | | | | | | | | | | X
HPV test | human papilloma virus cell swab | diagnosis | | | | | | | | | | | X
IGF-II | | prediction | | | | | | | | | | | X
IMI breast cancer test | | diagnosis | X
Immunocyt/ uCyt | | diagnosis | | | | | | | | | | | X
Iressa test | | management | | | X
Key2 | | diagnosis | X
K-ras | | detection | | | X | X
Leukemia Affymetrix Chip | | diagnosis | | | | | | | | | | X
Leukemia blood test | MRD test | recurrence | | | | | | | | | | X
lung cancer test | | diagnosis | | | X
lung cancer test | Electronic Nose | diagnosis | | | X
LungAlert | | diagnosis | | | X
lysophopholipids | LPA | detection | | | | | | X
M2-PK | | primary prevention | | | | X
MammaPrint | | management | X
matrix metalloproeinases | MMP | detection | | | | | | X
Melanoma inhibiting antigen | MIA | diagnosis | | | | | | | | | | | X
melastatin | mRNA expression | management | | | | | | | | | | | X
MESOMARK | | diagnosis | | | | | | | | | | | X
MGMT | methylation marker | detection | | | | X
Microsatelitte Analysis | Urine MicroSatellite Analysis | detection | | | | | | | | | | | X
MLH1 | methylation marker | detection | | | | X
MN protein | | detection | | | | | | X
MSA | | management | | | | | | | | | | | X
MSA analysis | microsatellite DNA | diagnosis | | | | | | | | | | | X
NAF test | | diagnosis | X
NMP179 | | diagnosis | | | | | | | | | | | X
NMP22 | Matritek's Bladderchek test | detection | | | | | | | | | | | X
NMP35 | | diagnosis | | | | X
NMP48 | | diagnosis | | X
NMP66 | | diagnosis | X
OncoVue breast cancer risk test | Tagit | primary prevention | X
Ovacheck | | diagnosis | | | | | | X
ovarian cancer biomarker test | | diagnosis | | | | | | X
ovarian cancer test | | diagnosis | | | | | | X
ovarian cancer test | Ovarian Cancer Prognostic Profile | management | | | | | | X
ovarian pap test | | detection | | | | | | X
p16, p15, p14 deletions | | management | | | | | | | | | | X | X
p202 | | management | | X
p53 Affymetrix Chip | | diagnosis | X
Prostate 63 | AsymmetRx | management | | X
prostate biomarkers | | management | | X
Prostate Cancer Blood Test | ProteomeDx | diagnosis | | X
Protein Profile test | lysophosphatidic acid (LPA) | recurrence | | | | | | X
PSA testing | in office | diagnosis | | X
PSMA | prostate specific membrane antigen | management | | X
PSP94 | prostate secratory protein | diagnosis | | X
PTEN tumor suppressor | | management | | X
PyloriProbe | DR70 | diagnosis | | | | X
Recaf | alpha feto protein receptor | diagnosis | X | X | X | X
RhoC GTPase | | management | X
S100 | | diagnosis | | | | | | | | | | | X
SELDI-TOF-MS | molecular profiling using SELDI | management | X | X | X | | | X
SurePath | | diagnosis | | | | | | | | | | | X
telomerase | hTR, HTerRT | diagnosis | | | | | | | | | | | X
TGF genes | | prognosis | X
TUO test | | diagnosis | | | | | | | | | | | X
uPM3 | PCA3 assay | diagnosis | | X
urinary plasminogen activator | suPAR | detection | | | | | | X
urine test for cervical cancer | | diagnosis | | | | | | | | | | | X
VEGF | | management | | | | X
WISP3 | | management | X

Name | other cancer | Developer | Data source
AFP-L3 | | Wako | LexisNexis
alpha Catenin | | | EDRN
APC | | | EDRN
BAT-26 | | | EDRN
bladder cancer test | bladder | ChondroGene, MSKCC | LexisNexis
BladderChek | bladder | M.D. Anderson C.C, Matritech Inc. | LexisNexis
Breast Cancer Detection | | IMI International | CHI
Breast Cancer Outcome Prediction Test | | Epigenomics, Roche Diagnostics | LexisNexis
Cancer antigen 72-4 | stomach | Roche Diagnostics | Roche Diagnostics
CDK family | | M.D. Anderson | LexisNexis
CDKN24 | | | EDRN
CDP/Cux | | DiagnoCure, McGill U. | LexisNexis
CellSearch | | Immunicon, Veridex. Quest Diagnostics | LexisNexis, CHI
CeMines CellCorrect Lab | | CeMines | LexisNexis
chromosome 8q gain | | | clinicaltrials.gov
c-Kit pharmDx | GIST | DakoCytomation | LexisNexis
colorectal cancer test | | Microprevention Tests | LexisNexis
colorectal gene panel | | Quest diagnostics | LexisNexis
Colorectalert | | IMI Medical | LexisNexis, CHI
Conversion Analysis | | GMP Companies, Cleveland Clinic | LexisNexis
Cox-2 RNA | | | EDRN
cPSA | | | FDA
CupPrint | tumor of unknown origin | Agendia | LexisNexis
Cyfra 21-1 | | Roche Diagnostics | Roche Diagnostics
Cytokeratin 20 | | Roche Diagnostics | Roche Diagnostics
CytoVision | | Applied Imaging Corp | LexisNexis
des-gamma carboxyprothrombin | | | EDRN
DNA methylation | kidney | | google news, CHI
DNA methylation | | Orion Genomics, Methexis, Roche, Sequenom | LexisNexis, CHI
EEF1A2 | | | CISTI
EGFR | cervical, endometrial | | EDRN, clinicaltrials.gov, CHI
EGFR | | Genzyme, DFCI, MGH | LexisNexis
EPCA | | Tessera, Johns Hopkins U | LexisNexis
eTag | | ViroLogic, AstraZeneca | LexisNexis, CHI
Genomic Test | | | clinicaltrials.gov
GOS | | | EDRN
GSTM1 | | | google news
GSTP1 | | | EDRN, google news
Her-1, Her-2, Her-3, Her-4 | | Roche Diagnostics | Roche Diagnostics
HLA-E | gliomas | | google news
HP1alpha | | | CISTI
HPV test | cervical | Diagene, GenoID | LexisNexis
HPV test | cervical | Roche Diagnostics | Roche Diagnostics
IGF-II | cervical, endometrial | | EDRN
IMI breast cancer test | | IMI Medical | LexisNexis
Immunocyt/ uCyt | bladder | DiagnoCure, Gen-Probe | LexisNexis
Iressa test | | U of Tokyo, AstraZeneca | LexisNexis
Key2 | | Exagen | LexisNexis
K-ras | | | EDRN
Leukemia Affymetrix Chip | | Roche Diagnostics | Roche Diagnostics
Leukemia blood test | | Genzyme | CHI
lung cancer test | | Cangen Biotech, Olympus | LexisNexis
lung cancer test | | Cleveland Clinic | LexisNexis
LungAlert | | IMI Medical | LexisNexis
lysophopholipids | | | clinicaltrials.gov
M2-PK | | Giessen U | LexisNexis
MammaPrint | | Agendia, Transbig, Molecular Profiling Institute | LexisNexis
matrix metalloproeinases | | | clinicaltrials.gov
Melanoma inhibiting antigen | melanoma | Roche Diagnostics | Roche Diagnostics
melastatin | melanoma | | clinicaltrials.gov
MESOMARK | mesothelioma | Fujirebio Diagnostics | LexisNexis
MGMT | | | EDRN
Microsatelitte Analysis | bladder | | clinicaltrials.gov
MLH1 | | | EDRN
MN protein | | | clinicaltrials.gov
MSA | bladder | | EDRN, clinicaltrials.gov
MSA analysis | bladder | Cangen Biotech | LexisNexis
NAF test | | Power3 | LexisNexis
NMP179 | cervical | Matritech Inc. | LexisNexis
NMP22 | bladder | | FDA/ CHI
NMP35 | | Matritech Inc. | LexisNexis
NMP48 | | Matritech Inc. | LexisNexis
NMP66 | | Matritech Inc. | LexisNexis, CHI
OncoVue breast cancer risk test | | Tm Bioscience/Intergenetics | LexisNexis, CHI
Ovacheck | | Quest, LabCorp, Correlogic | LexisNexis
ovarian cancer biomarker test | | Ciphergen Biosystems, Johns Hopkins | LexisNexis
ovarian cancer test | | Yale U | LexisNexis
ovarian cancer test | | Beth Israel Deaconess Medical Center | LexisNexis
ovarian pap test | | | clinicaltrials.gov
p16, p15, p14 deletions | ALL | | clinicaltrials.gov
p202 | | | CISTI
p53 Affymetrix Chip | others | Roche Diagnostics | Roche Diagnostics
Prostate 63 | | | CLIA
prostate biomarkers | | Health discovery Corporation/Stanford U | CHI
Prostate Cancer Blood Test | | Correlogic | CHI
Protein Profile test | | | clinicaltrials.gov
PSA testing | | Qualigen, Healthtronics | LexisNexis
PSMA | | Cytogen | CHI
PSP94 | | Procyon, Medicorp | LexisNexis
PTEN tumor suppressor | | | CISTI
PyloriProbe | | AMDL | LexisNexis
Recaf | | Abbot, BioCurex | LexisNexis
RhoC GTPase | | | CISTI
S100 | melanoma | Roche Diagnostics | Roche Diagnostics
SELDI-TOF-MS | | | EDRN
SurePath | cervical | Tripath Imaging | LexisNexis
telomerase | bladder | Roche Diagnostics | Roche Diagnostics
TGF genes | | | google news
TUO test | tumor of unknown origin | US LABS | LexisNexis
uPM3 | | DiagnoCure, Gen-Probe | LexisNexis
urinary plasminogen activator | | | clinicaltrials.gov
urine test for cervical cancer | cervical | U. Washington | LexisNexis
VEGF | | Quest | LexisNexis
WISP3 | | | CISTI

Name | Other
AFP-L3 | detects AFP-L3 presence
alpha Catenin
APC
BAT-26
bladder cancer test | gene expression profiling in blood cells
BladderChek | urine test for protein NMP22
Breast Cancer Detection
Breast Cancer Outcome Prediction Test | DNA methylation markers that correlate closely with prostate cancer aggressivness
Cancer antigen 72-4
CDK family | measures activity of CDK family enzymes which potentially assesses chemotherapy activity
CDKN24
CDP/Cux | proteins abnormally expressed in breast cancers
CellSearch | circulating tumor cells
CeMines CellCorrect Lab | test detects molecular fingerprints of disease-related autoantibodies in blood
chromosome 8q gain
c-Kit pharmDx | qualitatively identifies c-kit protein/ CD117 expression
colorectal cancer test | detect surface layer exfoliated epithelial cells
colorectal gene panel | evaluate likelihood of toxicity/response to 5FU, oxaliplatin, irinotecan
Colorectalert | sampling of rectal mucus/ clinical trial with EDRN initiated
Conversion Analysis | improved detection of genetic mutations associated with hereditary cancer
Cox-2 RNA
cPSA
CupPrint | gene expression
Cyfra 21-1
Cytokeratin 20
CytoVision | autosomal chromosomal analysis using FISH
des-gamma carboxyprothrombin
DNA methylation
DNA methylation | detects DNA methylation
EEF1A2
EGFR
EGFR | EGFR gene mutations
EPCA | blood test for EPCA
eTag | technology to improve analysis of HER factor family receptor
Genomic Test
GOS
GSTM1
GSTP1
Her-1, Her-2, Her-3, Her-4
HLA-E
HP1alpha
HPV test | HPV detection with Pap smear, identifies 51 types of HPV
HPV test
IGF-II
IMI breast cancer test | identifies cancer associated sugar in nipple aspirate fluid
Immunocyt/ uCyt | urine test for bladder cancer recurrence
Iressa test | determine response to Iressa
Key2 | detects changes in DNA copy number
K-ras
Leukemia Affymetrix Chip
Leukemia blood test
lung cancer test | hybrid DNA and protein test for detection of lung cancer
lung cancer test | detects 'smell prints' of numerous organix compounds in exhaled breath
LungAlert | sputum test for lung cancer
lysophopholipids
M2-PK | M2-PK protein in stool blood
MammaPrint | 70 gene expression signature
matrix metalloproeinases
Melanoma inhibiting antigen
melastatin
MESOMARK | blood test for soluble mesothelin related proteins
MGMT
Microsatelitte Analysis
MLH1
MN protein
MSA
MSA analysis | urine test using microsatelitte DNA analysis
NAF test | analyses 14 biomarkers found in breats ductal fluid
NMP179 | test for protein NMP179
NMP22
NMP35 | blood test for protein NMP35
NMP48 | blood test for protein NMP48
NMP66 | blood test for protein NMP66
OncoVue breast cancer risk test | breast cancer risk test/ mouthwash DNA test
Ovacheck | genomic blood test for detection of ovarian cancer
ovarian cancer biomarker test | protein array for detecting ovarian cancer
ovarian cancer test | blood test for 4 biomarkers
ovarian cancer test | gene expression profile (115 gene array) for prognosis
ovarian pap test
p16, p15, p14 deletions
p202
p53 Affymetrix Chip
Prostate 63
prostate biomarkers
Prostate Cancer Blood Test
Protein Profile test
PSA testing | measures PSA levels
PSMA
PSP94 | blood test for PSP94
PTEN tumor suppressor
PyloriProbe | quantifies fibrin degradation products in serum by a proprietary antibody
Recaf | potential biomarker for new cancer diagnostic tests
RhoC GTPase
S100
SELDI-TOF-MS
SurePath | biomarkers associated with cervical cancer
telomerase
TGF genes
TUO test | gene expression profiling of RNA for classification of Tumors of unknown origin
uPM3 | urine test for PCA3 gene and PSA mRNA
urinary plasminogen activator
urine test for cervical cancer | urine test for high risk cervical cancer
VEGF | predict response to bevacizumab
WISP3