# One page profiles of current genetic tests

Glossary of test acronyms used in this database

[underlined: Tests]

EIA: Enzyme immunoassay
FISH: Fluorescence in-situ hybridization
ICC: Immunocytochemistry
ICMA: Immunochemiluminometric assay
IHC: Immunohistochemistry
IRMA: Immunoradiometric assay
MEIA: Microparticle enzyme immunoassay
PCR: Polymerase chain reaction
RIA: Radioimmunoassay
RT-PCR: Reverse transcriptase polymerase chain reaction

1. Test name: | Acid phosphatase, total and prostatic
2. Other names: | PAP
3. Description: | Elevated levels of this enzyme are found in patients with metastatic prostate cancer. PAP determination, in conjunction with PSA measurements, is useful in assessing the prognosis of prostate cancer. Concentrations of both the prostatic and nonprostatic forms of acid phosphatase may be differentiated using tartrate. The activity of the prostatic form of the enzyme is inhibited in the presence of tartrate.
4. Purpose: | prognostic, recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | Serum, frozen
7. Methodology: | ICMA spectrophotometry - alpha-naphthol phosphate substrate with tartrate inhibition for prostatic AcP determination
8. Cancers: | prostate cancer
9. Other cancers:
10. Clinical use(s):; a. Routine:; - used as an adjunct in confirming the clinical staging of prostate cancer; - used with PSA to detect recurrence of prostate cancer in patients who have been treated
11. Source of information: | LabCorp, Specialty Laboratories, UpToDate™ websites
12. Exploratory Medline search (5/25/05):; a. “Acid phosphatase” = 2010 citations, “prostate” = 6127 citations; b. “Acid phosphatase” and “prostate” = 102 citations; c. “Acid phosphatase” and “prostatic neoplasm” (24856) = 111 citations; d. “Total acid phosphatase” (21) and “prostatic neoplasm” = 4 citations

1. Test name: | Adrenocorticotropic hormone
2. Other names: | ACTH hormone
3. Description: | ACTH has been used in diagnosing disorders of the hypothalamicpituitary system. It is useful in the differential diagnosis of Cushing syndrome, ectopic ACTH syndrome, Addison disease, hypopituitarism, and ACTH-producing pituitary tumors (eg, Nelson syndrome). The most common causes of ectopic ACTH syndrome are small (oat)-cell carcinomas, carcinoid tumors, particularly bronchial carcinoids, islet cell tumors, and pulmonary tumorlets.
4. Purpose: | diagnostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | plasma
7. Methodology: | ICMA
8. Cancers: | pituitary, adrenal
9. Other cancers: | carcinoid, thyroid, pulminary, pancreas
10. Clinical use(s):; a. Routine:; - used in the diagnosis of ectopic ACTH syndrome associated with small cell carcinoma, carcinoid tumors, and islet cell tumors
11. Source of information: | Quest Diagnostics, LabCorps, Specialty Laboratories, UpToDate™
12. Exploratory Medline search (5/26/05):; a. “corticotropin” = 6949 citations, “pituitary gland” = 11858 citations; b. “pituitary neoplasm” = 4542 citations; c. “corticotropin” and “pituitary gland” = 1873 citations; d. “corticotropin” and “pituitary neoplasm” = 423 citations; e. “corticotropin” and “ACTH syndrome, ectopic” = 84 citations

1. Test name: | Alpha-Fetoprotein
2. Other names: | AFP
3. Description: | Elevated serum AFP levels are most closely associated with nonseminomatous testicular cancer and hepatocellular cancer. The rate of clearance from serum after treatment is an indicator of the effectiveness of therapy. Conversely, the growth rate of progressive disease can be monitored by serially measuring serum AFP concentrations over time.
4. Purpose: | secondary prevention, prognostic, recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum protein
7. Methodology: | ICMA
8. Cancers: | non-seminomatous testicular, hepatocellular
9. Other cancers: | AFP may also be elevated in malignant germ cell tumors of ovary and testis, gastrointestinal, pancreatic, pulmonary cancer
10. Clinical use(s):; a. Routine:; - distinguish between seminomatous and non-seminomatous testicular germ cell cancer; - monitor effectiveness of therapy and detect recurrence in individuals with non- seminomatous testicular germ cell cancer; - monitor effectiveness of therapy in individuals with hepatocellular carcinoma; - monitor hepatitis B carriers for evidence of liver cancer; b. Investigational:; - elevated serum concentrations of AFP are found in 23% of patients with pancreatic, gastric (18%), bronchogenic (7%) and colonic carcinoma (5%), compared to 75% of patients with non-seminomatous testicular cancer and 72% of patients with hepatocellular cancer
11. Source of information: | Quest Diagnostics, LabCorp, Specialty Laboratories websites
12. Exploratory Medline search (5/12/05):; a. “alpha-Fetoproteins” = 2608 citations, “testicular neoplasms” = 4401 citations; b. “alpha-Fetoproteins” and “testicular neoplasm” = 113 citations; c. “alpha-Fetoproteins” and “carcinoma, hepatocellular” (13840) = 704 citations; d. “alpha-Fetoproteins” and “pancreatic neoplasms” (12117) = 27 citations; e. “alpha-Fetoproteins” and “gastrointestinal neoplasms” (64300) = 133 citations; f. “alpha-Fetoproteins” and “lung neoplasms” (36152) = 46 citations; g. “alpha-Fetoproteins” and “ovarian neoplasms”(15334) = 64 citations

1. Test name: | AML1/ETO translocation
2. Other names: | t(8:21)
3. Description: | The translocation t(8;21)(q22;q22) is one of the most common structural chromosomal aberrations in patients with Acute Myeloid Leukemia (AML). AML with t(8;21) has a mean onset age of about 30 years and is most common in children and younger adults; it is relatively rare in elderly patients. The presence of t(8;21) is associated with the highest complete remission rate (90%) and the highest probability (50%–70%) of remaining in complete remission at 5 years. However, the disease may become resistant to therapy upon relapse.
4. Purpose: | diagnostic, prognostic, recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | whole blood, bone marrow
7. Methodology: | PCR
8. Cancers: | acute myeloid leukemia
9. Other cancers:
10. Clinical use(s):; a. Routine:; - diagnosis of acute myeloid leukemia (AML) with t(8;21) chromosome translocation; - monitor treatment response; - detect minimal residual disease (MRD or evidence for the presence of residual cancer cells, even when so few malignant cells are present that they cannot be detected by routine means); - predict early relapse
11. Sources of information: | Quest Diagnostics, LabCorp, UpToDate
12. Exploratory Medline search (6/01/05):; a. “AML1” = 853 citations, “ETO” = 469 citations; b. “Leukemia, Myelocytic, Acute” = 4057 citations; c. “fusion protein” = 12573 citations; d. “Leukemia, Myelocytic, Acute” and “fusion protein” = 138 citations; e. “AML1” and “ETO” = 138 citations

1. Test name: | B-cell gene rearrangement
2. Other names:
3. Description: | These additional studies are used to establish a definitive diagnosis. They include molecular analysis of tumor material using PCR technology to identify gene rearrangements known to be associated with B-cell malignancies. Additionally the special tests can sometimes help to establish both the lineage and the presence of prognostically significant subtypes of malignant lymphoma.
4. Purpose: | diagnostic, prognostic, recurrence
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | whole blood, bone marrow, or tissue
7. Methodology: | PCR
8. Cancers: | B-cell malignancies
9. Other cancers:
10. Clinical use(s):; a. Routine:; - diagnosis of B-cell malignancies; - assist in determining disease prognosis and thus influence treatment selection; - detection of minimal residual disease or recurrent disease
11. Source of information: | Quest Diagnostics, LabCorps websites
12. Exploratory Medline search (6/01/05):; a. “B-Lymphocytes” = 17852 citations, “leukemia” = 38022 citations; b. “B-Lymphocytes” and “leukemia” = 1047 citations; c. “gene rearrangement” = 6400 citations; d. “B-Lymphocytes” and “gene rearrangement” = 1285 citations; e. “leukemia” and “gene rearrangement” = 1044 citations

1. Test name: | bcl-1/JH t(11;14) Gene Rearrangement
2. Other names: | t(11;14)
3. Description: | The t(11;14)(q13;q32) rearrangement causes deregulation of the bcl-1 gene and over-expression of cyclin D1, which may in turn lead to lymphoma genesis. The bcl-1 translocation is specific for mantle cell lymphoma
4. Purpose: | diagnostic, prognostic, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | whole blood, bone marrow, tissue
7. Methodology: | PCR
8. Cancers: | mantle cell lymphoma
9. Other cancers:
10. Clinical use(s):; a. Routine:; - diagnosis of mantle cell lymphoma; - assessment of therapeutic response; - detect minimal residual disease (MRD); - predict early relapse
11. Source of information: | Quest Diagnostics, LabCorp
12. Exploratory Medline search (6/01/05):; a. “genes, bcl-1” = 124 citations, “translocation” = 7571 citations; b. “mantle cell lymphoma” = 522 citations; c. “cyclin D1” = 2811 citations; d. “mantle cell lymphoma” and “cyclin D1” = 84 citations

1. Test name: | BCL-2 translocation
2. Other names: | t(14:18)
3. Description: | The bcl-2 gene translocation, t(14;18), is the rearrangement of the bcl-2 proto-oncogene on chromosome 18 with the immunoglobulin heavy chain region on chromosome 14. The bcl-2 translocation is a characteristic of Bcell lymphomas. It is observed in 70 to 90% of follicular non-Hodgkin Bcell lymphomas, 20 to 30% of large diffuse B-cell lymphomas, and 50% of undifferentiated B-cell lymphomas, but not in other lymphomas.
4. Purpose: | diagnostic, prognostic, recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, marrow, tissue
7. Methodology: | PCR
8. Cancers: | B-cell lymphomas
9. Other cancers:
10. Clinical use(s):; a. Routine:; - distinguish lymphoma from benign lymphoid hyperplasia; - distinguish B-cell lymphoma from T-cell lymphoma; - determine prognosis for patients with B-cell lymphomas; - monitor B-cell lymphoma patients for minimal residual disease or evidence of recurrence
11. Source of information: | Quest Diagnostics, UpToDate websites
12. Exploratory Medline search (6/01/05):; a. “Translocation, Genetic”= 7571 citations; b. “BCL-2 gene” = 1894 citations; c. “Lymphoma, B-Cell”= 9217 citations; d. “BCL-2 gene” and “Lymphoma” = 92 citations

1. Test name: | BCR-ABL
2. Other names: | Philadelphia chromosome
3. Description: | Bcr/abl fusion gene, formed by rearrangement of the breakpoint cluster region (bcr) on chromosome 22 with the c-abl proto-oncogene on chromosome 9, is present in 95% of CML patients and 30% of ALL patients. Identification of bcr/abl rearrangement is important for the diagnosis of CML, whereas in ALL, presence of bcr/abl is associated with poor prognosis and may warrant more aggressive therapy. In both diseases, increasing levels of bcr/abl may be associated with clinical progression.
4. Purpose: | diagnostic, prognostic, recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | whole blood, bone marrow RNA
7. Methodology: | PCR, FISH
8. Cancers: | Chronic Myelogenous Leukemia (CML) Acute Lymphocytic Leukemia (ALL)
9. Other cancers:
10. Clinical use(s):; a. Routine:; - assist in diagnosis of CML; - assess prognosis in ALL patients; - detect minimal residual disease and monitor effectiveness of therapy; - predict early relapse
11. Source of information: | Quest Diagnostics, LabCorp, Specialty Labs websites, UpToDate™
12. Exploratory Medline search (5/12/05):; a. “fusion proteins, bcr-abl” or “Philadelphia Chromosome” = 2008 citations; b. “leukemia, myeloid, chronic” = 4926 citations; c. “leukemia, lymphocytic, acute” = 4027 citations; d. “fusion proteins, bcr-abl” or “Philadelphia Chromosome” and “myeloid leukemia, chronic” = 1119 citations; e. “fusion proteins, bcr-abl” or “Philadelphia Chromosome” and “leukemia, lymphocytic, acute” = 151 citations

1. Test name: | Beta human chorionic gonadotropin
2. Other names: | beta-HCG
3. Description: | beta-hCG is detectable in the serum of 70% of patients with nonseminomatous germ-cell tumors. Patients with a prolonged half life of beta -hCG (>3.5 days) have an inferior overall and disease-free survival and may be candidates for high dose chemotherapy. In germ cell tumors in the male, beta-hCG and alpha-fetoprotein are both useful tumor markers
4. Purpose: | diagnostic, recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum
7. Methodology: | ICMA
8. Cancers: | germ cell tumors (e.g. teratoma, struma ovarii, dysgerminoma, yolk sac tumor, embryonal carcinoma, and choriocarcinoma)
9. Other cancers: | lung, pancreas, liver, stomach
10. Clinical use(s):; a. Routine:; - assist in the diagnosis of germ-cell tumors; - monitor response to trophoblastic tumor therapy; - detect disease recurrence; b. Investigational:; - monitor lung, pancreas, liver, stomach cancers
11. Source of information: | LabCorp, UpToDate, Specialty Labs websites
12. Exploratory Medline search (6/01/05):; a. “germinoma” = 2695 citations; b. “Chorionic Gonadotropin, beta Subunit, Human” = 1148 citations; c. “Chorionic Gonadotropin, beta Subunit, Human” and “germinoma” = 67 citations

1. Test name: | Beta 2-microglobulin
2. Other names:
3. Description: | Beta 2-microglobulin is increased nonspecifically in active chronic lymphocytic leukemia in which there is increased lymphocyte turnover. Elevated levels of beta 2-microglobulin can be found in cerebral spinal fluid (relative to serum) in acute lymphoblastic leukemia, lymphoma and other lymphoproliferative disorders. (Lymphoproliferative disorders refers to a group of malignant diseases involving the lymphoid cells and cells from the reticuloendothelial system, including lymphoma and posttransplant lymphoproliferative disorder). Increased serum concentrations of beta 2-microglobulin are good predictors of complete response and time to treatment failure in low-grade lymphoma.
4. Purpose: | diagnostic, prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum
7. Methodology: | ICMA
8. Cancers: | lymphoma, Hodgkin’s and Non-Hodgkin’s Lymphoma
9. Other cancers: | multiple myeloma, chronic lymphocytic leukemia, and other indolent lymphomas
10. Clinical use(s):; a. Routine:; - assist in diagnosis of lymphoma and other lymphoproliferative diseases; - predictive of response of low grade lymphoma
11. Source of information: | LabCorp, Specialty Labs, UpToDate
12. Exploratory Medline search (6/01/05):; a. “Lymphoproliferative Disorders” = 57926 citations; b. “Leukemia, Lymphocytic, Chronic” = 3353 citations; c. “beta 2-Microglobulin” = 2093 citations; d. “Lymphoproliferative Disorders” and “beta 2-Microglobulin” = 195 citations; e. “Leukemia, Lymphocytic, Chronic” and “beta 2-Microglobulin” = 19 citations

1. Test name: | Bladder Tumor Antigen
2. Other names: | BTA
3. Description: | A biomarker that is currently being investigated for use in surveillance following initial treatment of superficial bladder cancer.
4. Purpose: | recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | urine
7. Methodology: | cytology, EIA
8. Cancers: | bladder
9. Other cancers: | kidney and ureter
10. Clinical use(s):; b) Investigational:; - detection of tumor recurrence
11. Source of information: | Quest Diagnostics, LabCorp, UpToDate websites
12. Exploratory Medline search (6/01/05):; a. “bladder neoplasms” = 9404 citations; b. “tumor markers, biological” = 50524 citations; c. “bladder neoplasms” and “tumor markers, biological” = 1090 citations

1. Test name: | BRCA Analysis
2. Other names: | BRCA1, BRCA2
3. Description: | BRCA1 and BRCA2 are two susceptibility genes for breast cancer that are inherited in an autosomal dominant fashion and account for one-fifth of the familial risk of breast cancer. BRCA mutations are found in between 1 and 3.3 percent of American women with breast cancer who are unselected for family history. However, the prevalence of a deleterious BRCA1 or BRCA2 mutation in women of Ashkenazi Jewish (Eastern European) descent is approximately 2 percent.
4. Purpose: | primary prevention, prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | whole blood
7. Methodology: | PCR
8. Cancers: | breast, ovarian
9. Other cancers: | prostate, lymphoma, melanoma, cancers of the gallbladder, pancreas, stomach
10. Clinical use(s):; a. Routine:; - detection of BRCA1 and BRCA2 mutations which are associated with the majority of hereditary breast and ovarian cancers; - presence of BRCA1/2 gene mutations in patients with breast cancer may influence their treatment and management of their disease; - presence of BRCA1/2 gene mutations in a cancer patient may also result in additional testing for the mutation in family members of the BRCA positive patient
11. Source of information: | Quest, LabCorp, UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Breast Neoplasms” = 57,232 citations; b. “genes, BRCA1 or genes, BRCA2” = 2188 citations; c. “Breast Neoplasms” and “genes, BRCA1 or genes, BRCA2” = 1597 citations

1. Test name: | Calcitonin
2. Other names:
3. Description: | High concentrations of calcitonin occur in patients with malignant parafollicular or C-cell tumors of the thyroid gland. The doubling time of serum levels of this hormone correlates with recurrence of tumors.
4. Purpose: | secondary prevention, diagnostic, prognostic, recurrence
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum, frozen
7. Methodology: | ICMA
8. Cancers: | thyroid gland
9. Other cancers: | lung, breast, carcinoids, islet cell tumors, APUDomas
10. Clinical use(s):; a. Routine:; - detection of C-cell hyperplasia (the precursor of medullary carcinoma of thyroid); - used as a tumor marker for diagnosis and management of medullary carcinoma of the thyroid gland; b. Investigational:; - preoperative serum calcitonin is reported to roughly correlate with tumor weight or extent of disease
11. Source of information: | LabCorps, Specialty Laboratories, Quest, UpToDate websites
12. Exploratory Medline search (08/02/05):; a. “calcitonin” = 2434 citations; b. “thyroid neoplasms” = 9062 citations; c. “calcitonin” and “thyroid neoplasms” = 311 citations

1. Test name: | Cancer Antigen 125
2. Other names: | CA 125
3. Description: | CA 125 is expressed by >80% of non-mucinous ovarian epithelial neoplasms. Approximately half of women with metastatic ovarian cancer have an elevated CA 125 level.
4. Purpose: | recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum
7. Methodology: | MEIA, ICMA
8. Cancers: | ovarian
9. Other cancers: | lung, colorectal, pancreas, primary peritoneal carcinoma
10. Clinical use(s):; a. Routine:; - monitor response to treatment for patients with ovarian cancer; - detect recurrence of ovarian cancer
11. Source of information: | Quest Diagnostics, Specialty Laboratories, UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “CA-125 antigen” = 1391 citations; b. “ovarian neoplasms” = 15,743 citations; c. “CA-125 antigen” and “ovarian neoplasms” = 793 citations

1. Test name: | Cancer Antigen 15-3
2. Other names: | CA 15-3
3. Description: | Elevated serum CA 15-3 concentrations are found in 5% of stage I, 29% of stage II, 32% of stage III and 95% of stage IV carcinoma of the breast. Most (96%) patients with a CA 15-3 increase of greater than 25% have disease progression. Most (nearly 100%) patients with a CA 15-3 decrease of greater than 50% are responding to treatment.
4. Purpose: | recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum
7. Methodology: | ICMA
8. Cancers: | breast
9. Other cancers:
10. Clinical use(s):; a. Routine:; - tumor marker used to monitor clinical course in patients with metastatic disease; - change in CA 15-3 over time is predictive of response to therapy or progression of disease; - serum concentration correlates with tumor bulk
11. Source of information: | Specialty Laboratories, LabCorps, UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “CA-15-3 antigen” = 1629 citations; b. “breast neoplasm” = 57,603 citations; c. “CA-15-3 antigen” and “breast neoplasm” = 449 citations

1. Test name: | Cancer Antigen 19-9
2. Other names: | CA 19-9
3. Description: | CA 19-9 is a mucin-glycoprotein first identified from a human colorectal carcinoma cell line and is present in epithelial tissue of the stomach, gall bladder, pancreas and prostate. Concentrations are increased in patients with pancreatic, gastric, and colon cancer as well as in some nonmalignant conditions. Increasing levels generally indicate disease progression, whereas decreasing levels suggest therapeutic response.
4. Purpose: | recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum or plasma
7. Methodology: | EIA
8. Cancers: | colorectal, pancreatic, liver
9. Other cancers: | gastric
10. Clinical use(s):; a. Routine:; - monitor effectiveness of therapy in individuals with pancreatic cancer; - monitor effectiveness of therapy in selected individuals with gastric and colon cancer
11. Source of information: | Quest Diagnostics, LabCorps, and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “CA-19-9 antigen” = 816 citations; b. “colorectal neoplasm” = 37,826 citations; c. “CA-19-9 antigen” and “colorectal neoplasm” = 122 citations

1. Test name: | Cancer Antigen 27.29
2. Other names: | CA 27.29
3. Description: | Elevated CA 27.29 levels are primarily associated with metastatic breast cancer, where it can be used to monitor the course of disease, response to treatment, and detect disease recurrence. Elevated serum CA 27.29 concentrations are found in 95% of stage IV breast cancer. In addition, CA 27.29 has been found to be elevated in lung (43%), pancreas (47%), ovarian (56%), and liver (55%) cancer.
4. Purpose: | recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum protein
7. Methodology: | ICMA
8. Cancers: | breast
9. Other cancers: | may also be elevated in lung, pancreas, ovarian, and liver cancer
10. Clinical use(s):; a. Routine:; - in patients with metastatic breast cancer and an elevated level of this tumor marker, CA 27.29 can be used to monitor response to treatment, determine whether tumor has become resistant to therapy or whether a patient has progressive disease.
11. Source of information: | Quest Diagnostics, LabCorp, Specialty Labs websites
12. Exploratory Medline search (5/12/05):; a. “CA 27 29” or “CA 27-29” or “cancer antigen 27 29” = 18 citations; b. “breast neoplasm” = 55886 citations; c. “CA 27 29” and “breast neoplasms” = 16 citations; d. “CA 27 29” and “lung neoplasms”(36152) = 0 citations; e. “CA 27 29” and “pancreas neoplasms” (12117) = 0 citations; f. “CA 27 29” and “ovarian neoplasms” (15334) = 1 citations; g. “CA 27 29” and “liver neoplasms” (28088) = 2 citations

1. Test name: | Carcinoembryonic Antigen
2. Other names: | CEA
3. Description: | CEA is an oncofetal glycoprotein present in the gastrointestinal tract and body fluids of the embryo and fetus. It is also present in certain adult gastrointestinal cells, including the mucosal cells of the colorectum, and small amounts are present in blood. Blood levels are often elevated in patients with disseminated cancers and in some patients with nonmalignant disease.
4. Purpose: | secondary prevention, prognostic, recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum
7. Methodology: | ICMA
8. Cancers: | breast, lung, colorectal, pancreas, ovarian
9. Other cancers:
10. Clinical use(s):; a. Routine:; - monitor persistent, metastatic, or recurrent adenocarcinoma of the colon following curative surgery; - recommended for staging/prognosis, detecting recurrence, monitoring therapy, and screening for hepatic metastases in patients with colon cancer; b. Investigational:; - if CEA is elevated at the time of diagnosis and prior to initiation of treatment, it may be used to monitor response to therapy in patients with breast, lung, pancreas, ovarian cancers
11. Source of information: | Quest Diagnostics, LabCorps, and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “carcinoembryonic antigen” = 2785 citations; b. “breast neoplasm” or “lung neoplasm” or “colorectal neoplasm” or “pancreas neoplasm” or “ovarian neoplasm” = 162,473 citations; c. “carcinoembryonic antigen” and (b) = 1504 citations

1. Test name: | Cathepsin D
2. Other names:
3. Description: | This enzyme plays a critical role in protein catabolism and tissue remodeling. Over-expression is associated with non-ductal carcinoma and metastasis at the time of breast cancer diagnosis.
4. Purpose: | prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | tissue (formalin-fixed, paraffin-embedded)
7. Methodology: | IHC
8. Cancers: | breast
9. Other cancers:
10. Clinical use(s):; b) Investigational:; - high levels may have clinical significance in predicting decreased metastasis-free survival and decreased overall survival in women with node-negative breast cancer
11. Source of information: | Quest Diagnostics, LabCorps, and UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “cathepsin D” = 1001 citations; b. “breast neoplasm” = 57,603 citations; c. “cathepsin D” and “breast neoplasm” = 203 citations

1. Test name: | CBFB/MYH11 fusion protein
2. Other names: | inv(16), t(16;16)
3. Description: | This inversion results in fusion of the core binding factor ß (CBFß) gene on 16q22 with the smooth muscle myosin heavy chain gene (MYH11) on 16p13. This fusion protein accounts for 16% of the chromosomal aberrations associated with AML and patients with inv(16) or t(16;16) generally have relatively good response and long-term disease-free survival rates.
4. Purpose: | diagnostic, prognostic, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, marrow
7. Methodology: | PCR
8. Cancers: | acute myleomonocytic leukemia (AML subtype M4E0)
9. Other cancers:
10. Clinical use(s):; a. Routine:; - diagnosis of acute myelomonocytic leukemia (AML) with abnormal eosinophils, with inv(16) or t(16;16); - monitor effectiveness of treatment; - monitor minimal residual disease; - predict early relapse
11. Source of information: | Quest Diagnostic and UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “oncogene proteins, fusion” = 3798 citations; b. “leukemia, myelocytic, acute” = 4151 citations; c. “oncogene proteins, fusion” and “leukemia, myelocytic, acute” = 172 citations

1. Test name: | CD 117, c-kit
2. Other names: | Imatinib mesylate (Gleevec) sensitivity
3. Description: | The glycoprotein c-kit (CD117) is a member of the receptor tyrosine kinase subclass III family and has been implicated in a number of malignancies. Imatinib mesylate, a tyrosine kinase inhibitor, is effective in treating GISTs and other tumors that express c-kit
4. Purpose: | diagnostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | tissue
7. Methodology: | IHC
8. Cancers: | gastrointestinal stromal tumors, c-kit positive
9. Other cancers:
10. Clinical use(s):; a. Routine:; - determine eligibility for treatment with imatinib mesylate in patients with c-kit-positive gastrointestinal stromal tumors (GISTs)
11. Source of information: | Quest Diagnostics, UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “proto-oncogene protein c-kit” = 2022 citations; b. “gastrointestinal neoplasm” = 66,189 citations; c. “proto-oncogene protein c-kit” and “gastrointestinal neoplasm” = 367 citations

1. Test name: | CD 20
2. Other names: | rituximab (Rituxan) sensitivity
3. Description: | Rituximab is a genetically engineered, chimeric murine/human monoclonal antibody directed against the CD20 antigen found on the surface of normal and malignant B-cell lymphocytes. Since non- Hodgkin’s Lymphoma (NHL) subtypes may differ in their response to rituximab, determination of drug sensitivity is important for choosing therapy.
4. Purpose: | diagnostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood
7. Methodology: | flow cytometry
8. Cancers: | B-cell non-Hodgkin’s lymphoma
9. Other cancers:
10. Clinical use(s):; a. Routine:; - determine eligibility for rituximab (Rituxan; anti-CD20) treatment in patients with B-cell non-Hodgkin's lymphomas (NHL)
11. Source of information: | Quest Diagnostics, UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “antigens, cd20” = 1022 citations; b. “lymphoma, Non-Hodgkin” = 22,160 citations; c. “antigens, cd20” and “lymphoma, Non-Hodgkin” = 475 citations

1. Test name: | CD 25 (immunohistochemistry and flow cytometry)
2. Other names: | denileukin diftitox (Ontak) sensitivity
3. Description: | Denileukin diftitox (Ontak) is a cutaneous T-cell lymphoma (CTCL) therapy that targets the high-affinity interleukin-2 (IL-2) receptor. The IL- 2 receptor may exist in a low-affinity form (CD25), an intermediateaffinity form (CD122/CD132), and a high-affinity form (CD25/CD122/CD132). Patients whose malignant cells express the CD25 component of the IL-2 receptor may respond to Ontak therapy
4. Purpose: | diagnostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | tissue (IHC), blood or marrow (flow cytometry)
7. Methodology: | IHC or flow cytometry
8. Cancers: | cutaneous T-cell lymphoma
9. Other cancers:
10. Clinical use(s):; a. Routine:; - determine eligibility for denileukin diftitox treatment in patients with persistent or recurrent CTCL
11. Source of information: | Quest Diagnostics and UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “receptors, interleukin-2” = 4221 citations; b. “lymphoma, t-cell, cutaneous” = 2157 citations; c. “receptors, interleukin-2” and “lymphoma, t-cell, cutaneous” = 25 citations

1. Test name: | CD 33
2. Other names: | Gemtuzumab (Mylotarg) sensitivity
3. Description: | Gemtuzumab consists of a recombinant, humanized IgG kappa antibody conjugated to a cytotoxic anti-tumor antibiotic, calicheamicin, which binds specifically to the CD33 antigen. This antigen is found on the surface of leukemic blasts and immature normal cells of myelomonocytic lineage, but not in normal hematopoietic stem cells.
4. Purpose: | diagnostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, marrow
7. Methodology: | flow cytometry
8. Cancers: | acute myeloid leukemia (AML)
9. Other cancers:
10. Clinical use(s):; a. Routine:; - determine eligibility for gemtuzumab (Mylotarg, anti-CD33) treatment in patients with acute myeloid leukemia
11. Source of information: | Quest Diagnostics and UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “antigens, cd” = 88,193 citations; b. “leukemia, myelocytic, acute” = 4151 citations; c. “cd 33.mp” = 27 citations; d. “antigens, cd” and “leukemia, myelocytic, acute” = 435 citations

1. Test name: | CD 52
2. Other names: | alemtuzumab (Campath) sensitivity
3. Description: | CD52 is an antigen that can be expressed at high density on the surface of malignant CLL cells. Alemtuzumab is a humanized antibody targeted against CD52 and its binding is necessary for cell death and therapeutic response
4. Purpose: | diagnostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, marrow
7. Methodology: | flow cytometry
8. Cancers: | chronic lymphocytic leukemia (CLL)
9. Other cancers:
10. Clinical use(s):; a. Routine:; - determine eligibility for alemtuzumab (Campath, anti-CD52) treatment in patients with chronic lymphocytic leukemia
11. Source of information: | Quest Diagnostics and UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “antigens, cd” = 88,193 citations; b. “leukemia, lymphocytic, chronic” = 3422 citations; c. “cd 52.mp” = 13 citations; d. “antigens, cd” and “leukemia, lymphocytic, chronic” = 646 citations

1. Test name: | Chromosome 18q assay
2. Other names: | 18q/RER, DCC
3. Description: | Colorectal cancer patients having tumors with chromosome 18 deletion are more likely to have disease recurrence and have a shorter disease-free survival period when compared to patients with two copies of this chromosome
4. Purpose: | diagnostic, prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, tissue
7. Methodology: | PCR
8. Cancers: | colorectal cancer
9. Other cancers:
10. Clinical use(s):; a. Routine:; - diagnosis of colorectal disease; - predict recurrence of disease
11. Source of information: | LabCorps and UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “chromosomes, human, pair 18” = 1824 citations; b. “colorectal neoplasms” = 37,826 citations; c. “chromosomes, human, pair 18” and “colorectal neoplasms” = 108

1. Test name: | Colaris
2. Other names: | MLH1, MSH2
3. Description: | Hereditary nonpolyposis colorectal cancer (HNPCC) accounts for about 3% to 5% of colorectal cancers (CRCs) and is caused by defects in mismatch repair (MMR) enzymes. These defects may also increase the risk of endometrial, cervical, stomach, ovarian, and other forms of cancer. About 90% of individuals with HNPCC have mutations in 1 of 2 MMR genes, MLH1 or MSH2
4. Purpose: | secondary prevention, diagnostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood
7. Methodology: | PCR
8. Cancers: | colorectal
9. Other cancers: | endometrial, cervical, stomach, ovarian
10. Clinical use(s):; a. Routine:; - differentiate hereditary nonpolyposis colorectal cancer (HNPCC) from non-HNPCC colorectal cancer (CRC); - assess risk of HNPCC in family members of individuals with HNPCC
11. Source of information: | Quest Diagnostics, LabCorps, UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “colorectal neoplasm, hereditary nonpolyposis” = 1363 citations; b. “base pair mismatch” = 2251 citations; c. “colorectal neoplasm, hereditary nonpolyposis” and “base pair mismatch” = 268 citations

1. Test name: | Colaris AP
2. Other names: | APC, FAP
3. Description: | Used to identify patients who may have disease causing mutations by sequencing the coding region of the APC gene. Individuals with mutations in this gene are at risk for developing early onset of colon cancer. Identifying these mutations makes allows for presymptomatic diagnosis of familial adenomatous polyposis (FAP).
4. Purpose: | secondary prevention, diagnostic
5. Availability: | LabCorp
6. Specimen: | blood
7. Methodology: | PCR
8. Cancers: | colorectal
9. Other cancers:
10. Clinical use(s):; a. Routine:; - identify genetic predisposition to colorectal cancers associated with FAP
11. Source of information: | LabCorp website
12. Exploratory Medline search (8/2/05):; a. “genes, apc” = 1167 citations; b. “colorectal neoplasm, hereditary nonpolyposis” = 1363 citations; c. “genes, apc” and “colorectal neoplasm, hereditary nonpolyposis” = 57citations

1. Test name: | Cyclin D1
2. Other names:
3. Description: | D-type cyclins are predominantly expressed in the G1 phase of the cell cycle. The expression pattern of cyclin D1 has been extensively studied in certain cancer types including lymphoma and non-small cell lung cancer. Approximately 30% of breast carcinomas are Cyclin D1 positive. Over expression of Cyclin D1 is now a well established criterion for the diagnosis of Mantle Cell Lymphoma, a malignant, non-Hodgkin's lymphoma which is characterized by a unique chromosomal translocation t(11;14).
4. Purpose: | diagnostic, prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, tissue
7. Methodology: | FISH
8. Cancers: | mantle cell lymphoma
9. Other cancers:
10. Clinical use(s):; a. Routine:; - diagnosis of mantle cell lymphoma; - predict recurrence of disease
11. Source of information: | LabCorp and UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “cyclin d1” = 2877 citations; b. “lymphoma, mantle cell” = 539 citations; c. “cyclin d1” and “lymphoma, mantle cell” = 85 citations

1. Test name: | E-cadherin
2. Other names:
3. Description: | E-cadherin is a calcium-dependent epithelial cell-cell adhesion molecule that is associated with tumor invasiveness and disease progression. Ecadherin under-expression appears to be associated with poor tumor differentiation, progression following radical prostatectomy, and diminished overall survival.
4. Purpose: | prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | tissue
7. Methodology: | IHC
8. Cancers: | prostate
9. Other cancers:
10. Clinical use(s):; a. Routine:; - determine prognosis, predict tumor behavior and response to therapy
11. Source of information: | Quest Diagnostics and UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “cadherins” = 4880 citations; b. “prostatic neoplasm” = 25,690 citations; c. “cadherins” and “prostatic neoplasm” = 115 citations

1. Test name: | Epidermal growth factor receptor
2. Other names: | EGFR pharmDx, HER-1, Cetuximab (Erbitux) sensitivity
3. Description: | Dysregulation of the EGFR signaling pathway due to EGFR overexpression, genetic aberrations, or other causes leads to malignant transformation. Cetuximab inhibits binding of EGFR by EGF and transforming growth factor-α, thereby blocking downstream signal transduction pathways and arresting cell growth.
4. Purpose: | diagnostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | tissue
7. Methodology: | IHC
8. Cancers: | breast, prostate, lung, colorectal
9. Other cancers: | head and neck
10. Clinical use(s):; a. Routine:; - determine eligibility for cetuximab (Erbitux™') treatment
11. Source of information: | Quest Diagnostics and UpToDate websites
12. Exploratory Medline search (8/2/5):; a. “receptor, epidermal growth factor” = 6983 citations; b. “lung neoplasms or colorectal neoplasms or breast neoplasms or prostatic neoplasms” = 151,099 citations; c. “receptor, epidermal growth factor” and (b) = 1358 citations

1. Test name: | Estrogen/ progesterone receptor
2. Other names: | ER/PR
3. Description: | Breast cancers are dependent upon estrogen and/or progesterone for growth and that this effect is mediated through ERs and progesterone receptors (ER/PR). Both receptors may be over-expressed in malignant breast tissue.
4. Purpose: | diagnostic, prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | tissue
7. Methodology: | IHC
8. Cancers: | breast
9. Other cancers:
10. Clinical use(s):; a. Routine:; - predicts response to hormone therapy for women with advanced breast cancer and those receiving adjuvant treatment; - prognosticates the aggressiveness of a tumor
11. Source of information: | UpToDate website
12. Exploratory Medline search (8/2/05):; a. “receptors, estrogen” = 10,705 citations; b. “receptors, progesterone” = 3898 citations; c. “breast neoplasms” = 57,603 citations; d. “receptor, estrogen” and “receptors, progesterone” and “breast neoplasm” = 1452 citations

1. Test name: | Fecal globin
2. Other names: | InSure, FOBT
3. Description: | Cancerous and precancerous colorectal lesions tend to cause low-level bleeding. Annual screening with a fecal occult blood test (FOBT) can decrease colorectal cancer mortality by up to 33%.
4. Purpose: | secondary prevention
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | stool
7. Methodology: | IHC
8. Cancers: | colorectal
9. Other cancers:
10. Clinical use(s):; a. Routine:; - screen for lower gastrointestinal bleeding associated with colorectal cancer, adenomas, polyps, and other lower gastrointestinal conditions
11. Source of information: | Quest diagnostics, UpToDate websites
12. Exploratory Medline search (8/2/05):; a. “occult blood” = 1087 citations; b. “colorectal neoplasm” = 37,826 citations; c. “occult blood” and “colorectal neoplasm” = 825 citations

1. Test name: | FLT 3 mutation
2. Other names:
3. Description: | Mutations in FLT3 are common in AML and have been associated with poorer survival in children and in younger adults with normal cytogenetics receiving intensive chemotherapy
4. Purpose: | prognostic
5. Availability: | Quest Diagnostics
6. Specimen: | blood
7. Methodology: | PCR
8. Cancers: | acute myelogenous leukemia (AML)
9. Other cancers:
10. Clinical use(s):; a. Routine:; - predict survival in AML patients
11. Source of information: | Quest Diagnostics and UpToDate websites
12. Exploratory Medline search:; a. “receptor, protein, tyrosine kinase” = 28,203 citations; b. “leukemia, myelocytic, acute” = 4151 citations; c. “receptor, protein, tyrosine kinase” and “leukemia, myelocytic, acute” = 125 citations

1. Test name: | HER-2/neu
2. Other names: | c-erbB-2, trastuzumab (Herceptin) eligibility, HercepTest, PathVysion®
3. Description: | HER-2/neu is an oncogene encoding a growth factor receptor related to epidermal growth factor receptor (EGFR) and is amplified in approximately 25-30% of node-positive breast cancers. Over-expression of HER-2/neu is associated with decreased disease-free and overall survival. Over-expression of HER-2/neu may be used to identify patients who may be may benefit from trastuzumab (Herceptin™ ) and/or high dose chemotherapy. Trastuzumab is a humanized monoclonal antibody targeting the HER 2/neu (c-erbB-2) oncogene.
4. Purpose: | diagnostic, prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | tumor tissue, serum
7. Methodology: | IHC, FISH, EIA
8. Cancers: | breast
9. Other cancers: | HER2/neu may also be expressed in ovarian, gastric, colorectal, endometrial, lung, bladder, prostate, and salivary gland cancers
10. Clinical use(s):; a. Routine:; - assess prognosis of stage II, node positive breast cancer patients; - predict disease-free and overall survival in patients with stage II, node positive breast cancer treated with adjuvant cyclophosphamide, doxorubicin, 5-fluorouracil chemotherapy; - determine patient eligibility for Herceptin treatment; - College of American Pathologists (CAP) recommends FISH as an optimal method for HER2/neu testing; therefore, positive IHC results are usually confirmed by FISH testing; b. Investigational:; - HER2/neu may also be expressed in ovarian, gastric, colorectal, endometrial, lung, bladder, prostate, and salivary gland
11. Source of information: | Quest Diagnostics, LabCorp, Specialty Labs websites, UpToDate™
12. Exploratory Medline search (5/12/05):; a. “receptor, erbB-2” = 4028 citations; b. “receptor, erbB-2” and “breast neoplasms” (55886) = 1905 citations; c. “receptor, erbB-2” and “ovarian neoplasms” (15334) = 239 citations

1. Test name: | 5-HIAA
2. Other names: | 5-hydroxyindoleacetic acid
3. Description: | A serotonin analysis is most frequently performed for the diagnosis of carcinoid tumors of the small intestine. These tumors release large amounts of serotonin, which can produce the clinical syndrome of flushing, diarrhea, and right sided heart failure. 5-HIAA is the final metabolite of serotonin and is the most frequently used diagnostic test for carcinoid tumors.
4. Purpose: | diagnostic, prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | urine
7. Methodology: | liquid chromatography
8. Cancers: | carcinoid tumors
9. Other cancers:
10. Clinical use(s):; a. Routine:; - diagnosis of metastatic carcinoid tumors; b. Investigational:; - may be used as a prognostic factor in this disease; however, poor correlation exists between 5-HIAA level and clinical severity of carcinoid syndrome
11. Source of information: | LabCorp, UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Hydroxyindoleacetic Acid” = 1270 citations; b. “Carcinoid tumor” = 2255 citations; c. “Hydroxyindoleacetic Acid” and “Carcinoid tumor” = 78 citations

1. Test name: | Human papillomavirus hybrid capture
2. Other names: | HPV, ThinPrep
3. Description: | Human papillomavirus (HPV) infection is a common infection that is associated cancer. Although HPV infection does not always progress to cancer, >93% of cervical cancer cases are associated with HPV. This test detects 13 viral strains that are associated with an intermediate to high risk of cancer.
4. Purpose: | secondary prevention
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | pap smear
7. Methodology: | DNA probe cocktail
8. Cancers: | cervical cancer
9. Other cancers:
10. Clinical use(s):; a. Routine:; - determine need for colposcopy in individuals with atypical squamous cells of uncertain significance (ASCUS) found on Pap test; - assist in guiding patient management (as adjunct to cervical cytology)
11. Source of information: | Quest Diagnostics, UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Papillomavirus, Human” = 6318 citations; b. “Cervix Neoplasms” = 12280 citations; c. “Papillomavirus, Human” and “Cervix Neoplasms” 2661 citations

1. Test name: | IgVh mutation analysis
2. Other names:
3. Description: | Chronic lymphocytic leukemia (CLL) patients can be divided into 2 basic groups on the basis of the mutational status of the immunoglobulin heavychain variable-region (IgVH) gene in leukemic cells. Patients with IgVH mutations have longer survival than those without IgVH mutation. Thus, mutation analysis may be useful for planning management strategies.
4. Purpose: | prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, marrow
7. Methodology: | PCR
8. Cancers: | chronic lymphocytic leukemia (CLL)
9. Other cancers:
10. Clinical use(s):; a. Routine:; - assess prognosis for patients with CLL
11. Source of information: | Quest Diagnostics and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Immunoglobulin Variable Region” = 3919 citations; b. “Leukemia, Lymphocytic, Chronic” = 3422 citations; c. “Immunoglobulin Variable Region” and “Leukemia, Lymphocytic, Chronic” = 126 citations

1. Test name: | ImmunoCyt
2. Other names: | mucin, CEA
3. Description: | An immunocytochemistry assay for the detection of tumor cells shed in the urine of patients previously diagnosed with bladder cancer. This test is intended to augment the sensitivity of cytology for the detection of tumor cells in the urine of individuals previously diagnosed with bladder cancer.
4. Purpose: | recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | urine
7. Methodology: | cytology, ICC
8. Cancers: | bladder cancer
9. Other cancers:
10. Clinical use(s):; a. Routine:; - detection of tumor cells in the urine of individuals previously diagnosed with bladder cancer; - indicated for use in conjunction with cytoscopy as an aid in the management of bladder cancer
11. Source of information: | LabCorp and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Carcinoembryonic Antigen” = 2785 citations; b. “Bladder Neoplasms” = 9483 citations; c. “Carcinoembryonic Antigen” and “Bladder Neoplasms” = 33 citations

1. Test name: | Kappa/lambda light chain
2. Other names:
3. Description: | Elevated serum levels of monoclonal free light chains are associated with malignant plasma cell proliferation (eg. multiple myeloma), primary amyloidosis and light chain deposition disease. The appearance of higher levels of free light chains in the urine may be indicative of kidney disease or malignant lymphoproliferative disease such as multiple myeloma.
4. Purpose: | monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum, tissue, urine
7. Methodology: | IHC
8. Cancers: | multiple myeloma, lymphoproliferative disorders
9. Other cancers: | primary amyloidosis, light chain deposition disease
10. Clinical use(s):; a. Routine:; - detection of multiple myeloma
11. Source of information: | Quest Diagnostics, UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “immunoglobulins, light chains” = 2376 citations; b. “multiple myeloma” = 6154 citations; c. “lymphoproliferative disorders” = 59,066 citations; d. “immunoglobulins, light chains” and “multiple myeloma” = 258 citations; e. “immunoglobulins, light chains” and “lymphoproliferative disorders” = 534 citations

1. Test name: | LAP
2. Other names: | leukocyte alkaline phosphatase
3. Description: | Low LAP scores have been associated with CML, PNH, and thrombocytopenic purpura. In CML, regardless of the total WBC, the LAP score remains low. High LAP scores have been seen in polycythemia vera, myelofibrosis, aplastic anemia, hairy cell leukemia, leukemoid reactions, and Hodgkin’s disease.
4. Purpose: | diagnostic, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, bone marrow
7. Methodology: | enzyme assay
8. Cancers: | chronic myelocytic leukemia (CML)
9. Other cancers: | polycythemia vera, myelofibrosis, aplastic anemia, paroxysmal nocturnal hemoglobinuria, hairy cell leukemia, leukemoid reactions, lymphoma
10. Clinical use(s):; a. Routine:; - aids in differential diagnosis of chronic myelocytic leukemia vs. leukamoid reaction; - aids in evaluation of polycythemia vera, myelofibrosis with myeloid metaplasia, and paroxysmal nocturnal hemoglobinuria; b. Investigational:; - serial LAP scores can be a useful adjunct in evaluating the activity in Hodgkin’s disease, as well as its response to therapy.
11. Source of information: | Quest Diagnostics, UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “alkaline phosphatase ” = 7889 citations; b. “testicular neoplasm ” = 4487 citations; c. “alkaline phosphatase ” and “testicular neoplasm” = 34 citations

1. Test name: | Lipid associated sialic acid
2. Other names: | LASA; Lipid-Bound Sialic Acid
3. Description: | Elevations in blood LASA levels have been reported in patients with mammary (63%), gastroenteric (65%), pulmonary (79%), and ovarian (94%) neoplasms as well as those with leukemia (86%), lymphoma (87%), melanoma (84%), sarcoma (97%), and Hodgkin disease (91%). As a result, this assay may not have high specificity or sensitivity necessary for cancer detection.
4. Purpose: | recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum
7. Methodology: | spectrophotometry
8. Cancers: | breast, lung, colorectal, pancreas, ovarian, liver, lymphoma, leukemia, melanoma, neuroblastoma, uterine, sarcoma
9. Other cancers:
10. Clinical use(s):; a. Investigational:; - monitoring the course of therapy; - detecting disease recurrence
11. Source of information: | LabCorps website
12. Exploratory Medline search (8/02/05):; a. “lipid associated sialic acid.mp” = 15 citations; b. “N-acetylneuraminic acid” = 1496 citations; c. “neoplasms” = 571,042 citations; d. “lipid associated sialic acid.mp” and “neoplasms” = 9 citations; e. “N-acetylneuraminic acid” and “neoplasms” = 194 citations

1. Test name: | Melaris
2. Other names: | p16
3. Description: | p16 is a tumor suppressor gene that regulates cellular proliferation and growth by acting as a cyclin-dependent kinase 4 (CDK4) inhibitor. This test determines if a patient has a p16 gene mutation, indicating a predisposition for melanoma and pancreatic cancer.
4. Purpose: | primary prevention
5. Availability: | myriadtests.com
6. Specimen: | blood
7. Methodology: | PCR
8. Cancers: | melanoma, pancreas
9. Other cancers:
10. Clinical use(s):; a. Routine:; - screening for hereditary melanoma
11. Source of information: | Myriad Tests website
12. Exploratory Medline search (8/02/05):; a. “genes, p16” = 990 citations; b. “melanoma” = 17,770 citations; c. “neoplasms, pancreatic” = 12,470 citations; d. “genes, p16” and “melanoma” = 136 citations; e. “genes, p16” and “pancreatic neoplasms” = 66 citations

1. Test name: | MIB-1 antibody
2. Other names: | Ki-67 antigen
3. Description: | There is a strong correlation between proliferation rate and clinical outcome in a variety of tumor types and measurement of cell proliferative activity is an important prognostic marker. This marker correlates with flow cytometric S-phase
4. Purpose: | prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | tissue
7. Methodology: | IHC
8. Cancers: | breast, lymphomas, anaplastic large cell non-Hodgkin’s lymphoma
9. Other cancers:
10. Clinical use(s):; a. Routine:; - tissue marker for large cell non-Hodgkin’s lymphoma; - assess tumor proliferative rate, determine disease prognosis; - direct disease management
11. Source of information: | Quest Diagnostics, LabCorp, Specialty Laboratories Websites
12. Exploratory Medline search (8/02/05):; a. “Ki-67 Antigen” = 4840 citations; b. “Lymphoma, Non-Hodgkin” = 22160 citations; c. “Ki-67 Antigen” and “Lymphoma, Non-Hodgkin” = 117 citations

1. Test name: | Micrometastasis detection
2. Other names: | cytokeratins
3. Description: | Cytokeratins are expressed by both normal and malignant epithelial cells, but not by lymph node or bone marrow cells. Thus, the presence of cytokeratin-positive cells in lymph nodes or the bone marrow is suggestive of metastatic tumor. Multiple chromosomal aberrations in these suspected cytokeratin-positive micrometastases further substantiate that these cells are tumor cells.
4. Purpose: | recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | marrow, tissue
7. Methodology: | IHC
8. Cancers: | breast
9. Other cancers:
10. Clinical use(s):; a. Routine:; - detect micrometastases of epithelial cell origin (e.g., breast cancer); - determine the stage of epithelial cancers; - predict cancer recurrence/relapse and overall prognosis
11. Source of information: | Specialty Laboratories, Quest Diagnostics websites
12. Exploratory Medline search (8/02/05):; a. “cytokeratin” or “keratin” = 8784 citations; b. “Breast Neoplasms” = 57603 citations; c. “Neoplasm Metastasis” = 32119 citations; d. “cytokeratin” or “keratin” and “Breast Neoplasms” and “Neoplasm Metastasis” = 263 citations

1. Test name: | Microsatellite instability
2. Other names: | MSI, BAT 26, RER+
3. Description: | MSI is a marker for faulty DNA repair and is found in 90% of patients with hereditary non-polyposis colorectal cancer (HNPCC) but in only 15% of sporadic colorectal tumors. HNPCC (Lynch syndrome) is characterized by an autosomal dominant inheritance pattern of early-onset predisposition to colorectal cancer (average age 44 years). MSI is helpful in determining if colorectal cancer is due to HNPCC and whether further genetic testing of patients or their family members for HNPCC-associated mutations
4. Purpose: | primary and secondary prevention, diagnostic, prognostic
5. Availability: | commercial labs, academic institutions
6. Specimen: | blood, tumor tissue DNA
7. Methodology: | PCR
8. Cancers: | hereditary non-polyposis colorectal cancer
9. Other cancers:
10. Clinical use(s):; b) Investigational:; - identify colorectal tumors with high microsatellite instability; - identify individuals at risk for HNPCC; - identifying HNPCC in affected patients is also important since close surveillance of at-risk family members has been found to reduce the rate of colorectal cancer and overall mortality by >60%
11. Source of information: | Quest Diagnostics, LabCorp, Specialty Labs websites, UpToDate™
12. Exploratory Medline search (5/12/05):; a. “microsatellite repeats” = 15030 citations; b. “colorectal neoplasms” = 36712 citations; c. “colorectal neoplasms, hereditary nonpolyposis” = 1318 citations; d. “microsatellite repeats” and “colorectal neoplasms” = 1217 citations; e. “microsatellite repeats” and “colorectal neoplasms, hereditary nonpolyposis” = 410 citations

1. Test name: | MLH1, MSH2, MSH6 mutations
2. Other names: | HNPCC mismatch repair gene
3. Description: | About 90% of individuals with HNPCC have mutations in 1 of 2 mismatch repair (MMR) genes, MLH1 or MSH2. Mutations in MSH6, PMS1, and PMS2 have also been implicated in this malignancy. These genes are responsible for correcting nucleotide base mispairs and small insertions or deletions that occur during DNA replication. The lifetime risk of colorectal cancer in individuals with an MMR gene mutation is about 80%.
4. Purpose: | primary prevention
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood
7. Methodology: | PCR
8. Cancers: | colorectal
9. Other cancers:
10. Clinical use(s):; a. Routine:; - differentiate hereditary non-polyposis colorectal cancer (HNPCC) from non-HNPCC colorectal cancer; - assess risk of HNPCC in family members of individuals with HNPCC
11. Source of information: | Quest Diagnostics and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “MLH1” = 1285 citations; b. “MSH2” = 887 citations; c. “MSH6” = 294 citations; d. “colorectal neoplasm” = 37826 citations; e. (“MLH1” or “MSH2” or “MSH6”) and “colorectal neoplasms” = 792 citations

1. Test name: | Neuron specific enolase
2. Other names: | NSE
3. Description: | NSE is a glycolytic enzyme that catalyzes the conversion of phosphoglycerate to phosphoenol pyruvate. Elevated NSE concentrations are observed in patients with neuroblastoma, pancreatic islet cell carcinoma, medullary thyroid carcinoma, pheochromocytoma and other neuroendocrine tumors. Additionally, NSE levels are frequently increased in patients with small cell lung cancer (SCLC) and infrequently in patients with non-SCLC.
4. Purpose: | monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum
7. Methodology: | RIA
8. Cancers: | lung, pancreas
9. Other cancers: | neuroblastoma, carcinoma, medullary thyroid carcinoma, pheochromocytoma and other neuroendocrine tumors
10. Clinical use(s):; a. Routine:; - monitor disease progression and therapy in individuals with small cell lung cancer; - monitor effectiveness of therapy in various other cancers
11. Source of information: | Specialty Laboratories, Quest Diagnostics Websites
12. Exploratory Medline search (8/02/05):; a. “neuron specific enolase” = 1577 citations; b. “lung neoplasms” = 37232 citations; c. “neuron specific enolase” and “lung neoplasms” = 223 citations

1. Test name: | Nuclear matrix proteins
2. Other names: | NMP 22
3. Description: | Nuclear matrix proteins (NMPs) are associated with functions such as DNA replication and RNA synthesis. Identification of increased concentrations of NMP 22 can aid in the management of patients with transitional cell carcinoma of the urinary tract and also in the differential diagnosis of persons with symptoms or risk factors for transitional cell carcinoma of the bladder
4. Purpose: | diagnostic, recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | urine
7. Methodology: | EIA
8. Cancers: | bladder
9. Other cancers:
10. Clinical use(s):; a. Routine:; - diagnosis of bladder cancer; - monitor patients for bladder cancer recurrence
11. Source of information: | Quest Diagnostics, LabCorp websites
12. Exploratory Medline search (8/02/05):; a. “nuclear matrix-associated proteins”= 830 citations; b. “NMP 22” = 25 citations; c. “bladder neoplasms” = 9483 citations; d. “NMP 22” and “neoplasms, bladder” = 23 citations; e. “nuclear matrix-associated proteins” and “bladder neoplasms” = 3 citations

1. Test name: | Oncotype DX™
2. Other names: | breast cancer assay
3. Description: | Oncotype DX is an assay that quantifies the likelihood of breast cancer recurrence in women with newly diagnosed, stage I or II, node negative, estrogen receptor positive breast cancer who will be treated with Tamoxifen. The assay analyzes the expression of a panel of 21 genes and the results are provided as a Recurrence Score™ (0-100). Using the Recurrence score, patients are classified into low, intermediate, and high risk categories for likelihood of disease recurrence.
4. Purpose: | prognostic
5. Availability: | limited commercial availability via Genomic Health (Redwood City, CA), academic institutions participating in clinical trials
6. Specimen: | tumor tissue RNA
7. Methodology: | PCR
8. Cancers: | breast
9. Other cancers:
10. Clinical use(s):; a. Investigational:; - to assess risk of recurrence in certain breast cancer patients and thus aid in treatment planning
11. Source of information: | Genomic Health website and promotional material
12. Exploratory Medline search (5/12/05):; a. “gene assay” = 599 citations; b. “breast neoplasms” = 55,886 citations; c. “gene assay” and “breast neoplasms” = 33 citations; d. “oncotype dx” or “oncotype” = 4 citations; e. company website = 11 citations: 2 publications, 9 abstracts

1. Test name: | p53 tumor suppressor gene
2. Other names: | p53
3. Description: | p53 is a tumor suppressor gene and normally has an inhibitory influence on the cell cycle. Once this gene is deleted or its function reduced, normal control mechanisms are altered. Alterations of the p53 tumor suppressor gene have been shown to serve as a powerful prognostic marker in a wide variety of tumor types such as colorectal, breast, prostate, and bladder. Additionally, alterations of p53 are associated with tumor recurrence and shorter disease-free survival.
4. Purpose: | prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | tissue
7. Methodology: | IHC
8. Cancers: | breast, prostate, colorectal
9. Other cancers: | bladder
10. Clinical use(s):; a. Routine:; - determine prognosis in patients with colorectal, breast, prostate, bladder cancers; - predict disease recurrence; - predict disease free survival
11. Source of information: | Quest Diagnostics, LabCorp, and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “genes, P53” = 7910 citations; b. “colonic neoplasms” = 15,654 citations; c. “genes, P53” and “colonic neoplasms” = 276 citations

1. Test name: | PML/RARA translocation
2. Other names: | t(15;17)
3. Description: | More than 99% of (acute promyelocytic leukemia) APL patients harbor a translocation between chromosomes 15 and 17, which fuses the retinoic acid receptor alpha (RARA) gene on chromosome 17 with the PML gene on chromosome 15. Historically one of the most lethal forms of acute myeloid leukemia, APL leads to disseminated intravascular coagulation and death when not diagnosed and treated. Treatment with all-transretinoic acid substantially improves survival in patients who have failed anthracycline chemotherapy or for whom anthracycline is contraindicated.
4. Purpose: | diagnostic, prognostic, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, marrow
7. Methodology: | PCR
8. Cancers: | acute promeylocytic leukemia
9. Other cancers:
10. Clinical use(s):; a. Routine:; - diagnosis of acute promyelocytic leukemia (APL); - predict response to all-trans-retinoic acid or arsenic trioxide therapy; - assess effectiveness of therapy; - detection of minimal residual disease (MRD); - predict early relapse
11. Source of information: | Quest Diagnostics, UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “translocation, genetic” = 7693 citations; b. “leukemia, promyelocytic, acute” = 1954 citations; c. “translocation, genetic” and “leukemia, promyelocytic, acute” = 274 citations

1. Test name: | PreGen-26
2. Other names: | MSI, BAT-26
3. Description: | Isolates human DNA in stool and detects microsatellite instability usually associated with HNPCC and in a subset of sporadic colorectal cancers. PreGen-26 identifies alterations in the BAT-26 mononucleotide marker, believed to be the most frequent alteration found in tissue in HNPCC. BAT-26 microsatellite instability is present in as many as 90% of the colorectal cancers that occur in patients with HNPCC. PreGen-26 results can help to determine which patients are likely to have the presence of cancer with BAT-26 MSI.
4. Purpose: | primary and secondary prevention, monitoring
5. Availability: | LabCorp
6. Specimen: | stool DNA
7. Methodology: | PCR
8. Cancers: | colorectal
9. Other cancers:
10. Clinical use(s):; a. Routine:; - adjunct to colonoscopy for monitoring patients with HNPCC and family members of patients with HNPCC; - may be used as an alternative method to monitor patients with known or suspected HNPCC syndrome who are non-compliant with current screening recommendations
11. Source of information: | Exact Sciences, LabCorp websites
12. Exploratory Medline search (8/02/05):; a. “microsatellite repeats” = 15,424 citations; b. “colorectal neoplasms” = 37,826 citations; c. “microsatellite repeats” and “colorectal neoplasms” = 1265 citations

1. Test name: | PreGen-Plus™
2. Other names: | DNA-based colorectal cancer test
3. Description: | PreGen-Plus is a noninvasive screening test designed to detect clinically significant colorectal cancer. PreGen-Plus consists of a panel of 23 individual tests, each looking for the presence of mutations in human DNA isolated from stool. Three distinct technologies look for the presence of mutations in the k-ras oncogene, the APC and p53 tumor suppressor genes, shortened forms of BAT-26 (microsatellite instability), and a novel marker for disordered apoptosis.
4. Purpose: | secondary prevention, monitoring
5. Availability: | developed by EXACT Sciences, available commercially at LabCorp exclusively
6. Specimen: | stool DNA
7. Methodology: | PCR
8. Cancers: | colorectal
9. Other cancers:
10. Clinical use(s):; b) Investigational:; - detection of clinically significant colorectal neoplasia in asymptomatic, average-risk patients 50 years old and older; - an adjunctive test for those patients who receive an fecal occult blood test (FOBT), flexible sigmoidoscopy, or colonoscopy; - may enhance current methods for early detection of colorectal cancer
11. Source of information: | Exact Sciences, LabCorp websites
12. Exploratory Medline search (5/12/05):; a. “genes, ras” or “genes, apc” or “genes, p53” or “microsatellite, repeats” = 26861 citations; b. “colorectal neoplasms” = 36712 citations; c. “feces” and “DNA” = 1162 citations; d. “feces” and “DNA” and “colorectal neoplasms” = 62 citations; e. a) and d) = 25 citations

1. Test name: | Prostate Specific Antigen
2. Other names: | PSA: free, total, ultra-sensitive, with HAMA
3. Description: | PSA is elevated in about 30% of all cases with nodular prostatic enlargement. Circulating PSA exists as two major forms: complexed and free. Bound PSA is found in higher concentrations in patients with prostate cancer and free-PSA concentrations are higher in patients with Benign prostatic hypertrophy (BPH). PSA can be used to aid in the management of patients following surgical or medical treatment for prostate cancer.
4. Purpose: | secondary prevention, prognostic, recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood
7. Methodology: | ICMA, IRMA, EIA, MEIA
8. Cancers: | prostate
9. Other cancers:
10. Clinical use(s):; a. Routine:; - detection of early prostate cancer; - improve accuracy of staging prior to surgery; - monitor patient response to therapy; - detect disease recurrence
11. Source of information: | Quest Diagnostics, Specialty Labs, Abbott Diagnostics, UpToDate
12. Exploratory Medline search (8/02/05):; a. “prostate-specific antigen” = 7096 citations; b. “prostatic neoplasms” = 25,690 citations; c. “prostate-specific antigen” and “prostatic neoplasms” = 6084 citations

1. Test name: | T-cell receptor gene rearrangement
2. Other names:
3. Description: | Study intended to provide some evidence that can help to distinguish between benign lymphadenopathy and malignant lymphoma. Specifically used to detect clonal gene rearrangements in the T-cell receptor beta-chain constant region. The presence of a monoclonal gene rearrangement usually, but not always, reflects the presence of a T-lymphocytic neoplasm while polyclonal gene rearrangement patterns are found in benign reactive conditions.
4. Purpose: | diagnostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, marrow, tissue
7. Methodology: | Southern blot analysis
8. Cancers: | T-cell malignancies, lymphomas and leukemias
9. Other cancers:
10. Clinical use(s):; a. Routine:; - diagnosis of T-cell malignancies; - leukemia and lymphoma lineage determination for prognosis and treatment selection; - detection of minimal residual disease or recurrent disease
11. Source of information: | LabCorp and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Gene Rearrangement, T-Lymphocyte” = 1735 citations; b. “Lymphoma, T-Cell” = 4837 citations; c. “Gene Rearrangement, T-Lymphocyte” and “Lymphoma, T-Cell” = 303 citations

1. Test name: | TEL/AML 1 gene fusion
2. Other names: | t(12;21)
3. Description: | The TEL/AML1 is a gene fusion resulting from a t(12;21)(p13;q22) chromosomal translocation. Although it occurs in only about 3% of adult acute lymphoblastic leukemia (ALL) cases, it is the most common genetic rearrangement in B-lineage pediatric ALL (frequency ~25%). The TEL/AML1 gene fusion is associated with a more favorable prognosis as evidenced by a significantly lower relapse rate.
4. Purpose: | diagnostic, prognostic, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, marrow
7. Methodology: | FISH
8. Cancers: | leukemia, acute lymphoblastic leukemia
9. Other cancers:
10. Clinical use(s):; a. Routine:; - differential diagnosis of acute lymphoblastic leukemia (ALL); - determine prognosis of patients with ALL; - monitor patients with ALL
11. Source of information: | Quest Diagnostics, UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Oncogene Proteins, Fusion” = 3798 citations; b. “Leukemia, Lymphocytic, Acute” = 7786 citations; c. “Oncogene Proteins, Fusion” and “Leukemia, Lymphocytic, Acute” = 453 citations

1. Test name: | Thyroglobulin
2. Other names:
3. Description: | Thyroglobulin is elevated in differential thyroid tumors. Thyroglobulin is a tumor marker useful to assess the presence of residual papillaryfollicular carcinoma of thyroid, following resection, including tumors that fail to concentrate radioiodine. Additionally, thyroglobulin assays are used to monitor postoperative thyroid carcinoma patients.
4. Purpose: | recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum
7. Methodology: | ICMA
8. Cancers: | thyroid carcinoma
9. Other cancers:
10. Clinical use(s):; a. Routine:; - detection of residual disease following resection; - monitor therapeutic response; - detect disease recurrence
11. Source of information: | LabCorp and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Thyroglobulin” = 1501 citations; b. “Thyroid neoplasms” = 9062 citations; c. “Thyroglobulin” and “Thyroid neoplasms” = 578 citations

1. Test name: | Tumor antigen 90 immune complex
2. Other names: | TA90-IC
3. Description: | TA90 is a 90-kd tumor-associated antigen that is expressed by >70% of melanomas. After curative resection of malignant melanoma, patients with occult metastasis may exhibit elevated levels of a TA90-IgG immune complex. TA90-IC is a sensitive and specific marker of recurrence in patients with malignant melanoma and is associated with shortened survival.
4. Purpose: | prognostic, recurrence, monitoring
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | serum
7. Methodology: | EIA
8. Cancers: | melanoma
9. Other cancers:
10. Clinical use(s):; a. Routine:; - assess prognosis after curative resection of malignant melanoma; - monitor patients for melanoma recurrence after curative resection
11. Source of information: | Quest Diagostics and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Melanoma” = 17,770 citations; b. “Antigens, Neoplasm” = 25,465 citations; c. “Melanoma” and “Antigens, Neoplasm” = 1128 citations

1. Test name: | Urokinase plasminogen activator
2. Other names: | uPA, PAI-1 (plasminogen activator inhibitor)
3. Description: | The serine protease urokinase-type plasminogen activator (uPA) and its primary inhibitor, plasminogen activator inhibitor-1 (PAI-1), have shown promise for risk assessment and prediction of therapeutic response in primary breast cancer. High levels of uPA or PAI-1 in primary tumor tissue are associated with an aggressive disease course and poor prognosis in both node-positive and node-negative breast cancer.
4. Purpose: | prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | tissue
7. Methodology: | EIA
8. Cancers: | breast
9. Other cancers:
10. Clinical use(s):; a. Routine:; - assess risk of breast cancer recurrence after primary treatment; - assess need for adjuvant therapy in women with lymph node-negative breast cancer; - predict therapeutic response to adjuvant chemotherapy
11. Source of information: | Quest diagnostics
12. Exploratory Medline search (8/02/05):; a. “Plasminogen Activator Inhibitor 1” = 3320 citations; b. “Urinary Plasminogen Activator” = 3442 citations; c. “Breast Neoplasms” = 57,603 citations; d. “Plasminogen Activator Inhibitor 1” and “Breast Neoplasms” = 142 citations

1. Test name: | Urovysion
2. Other names: | Vysis Urovision
3. Description: | Detects chromosomal abnormalities associated with the development and progression of bladder cancer. Specifically, this test detects aneuploidy of chromosomes 3, 7, 17, and loss of the 9p21 locus. It detects high grade pT1 and pTis tumors that can be overlooked with traditional diagnostic methods and have high progression rates to muscle-invasive cancer
4. Purpose: | recurrence
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | urine
7. Methodology: | FISH
8. Cancers: | bladder
9. Other cancers:
10. Clinical use(s):; a. Routine:; - detection of bladder cancer recurrence
11. Source of information: | Quest Diagnostics, Urovision, and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Urovysion” = 17 citations; b. “Bladder Neoplasms” = 9483 citations; c. “Urovysion” and “Bladder Neoplasms” = 16 citations

1. Test name: | ZAP-70
2. Other names:
3. Description: | ZAP-70 is a 70-kD member of the Syk family of protein tyrosine kinases. It is expressed primarily in T-cells and natural killer (NK) cells and is critical for signal transduction following T-cell receptor engagement. In CLL B-cells, elevated ZAP-70 expression appears to predict the need for therapy as effectively as IgVH mutation status. Although ZAP-70 expression is strongly correlated with IgVH mutation status, the combination of the 2 markers may provide greater prognostic value than either marker alone. Positive ZAP-70 results predict an aggressive disease course.
4. Purpose: | prognostic
5. Availability: | commercial laboratories, academic hospitals
6. Specimen: | blood, marrow
7. Methodology: | flow cytometry
8. Cancers: | CLL
9. Other cancers:
10. Clinical use(s):; a. Routine:; - assess prognosis and need for aggressive therapy in patients with chronic lymphocytic leukemia (CLL)
11. Source of information: | Quest Diagnostics and UpToDate websites
12. Exploratory Medline search (8/02/05):; a. “Protein-Tyrosine Kinase” = 45983 citations; b. “Leukemia, Lymphocytic, Chronic” = 3422 citations; c. “Protein-Tyrosine Kinase” and “Leukemia, Lymphocytic, Chronic” = 62 citations