# Genetic tests currently available

NAME | Other names | Primary prevention | Secondary prevention | Diagnostic | Prognostic | Recurrence | Monitoring | Specimen
Acid phosphatase, total and prostatic | PAP | | | | x | x | x | serum
Adrenocorticotropic hormone | ACTH | | | x | | | | plasma
Alpha fetoprotein | AFP | | x | | x | x | x | serum
AML1/ETO translocation | t(8;21) | | | x | x | x | x | blood, marrow
B-cell gene rearrangement | | | | x | x | x | | blood, marrow, tissue
BCL-1/JH gene rearrangement | t(11;14) | | | x | x | | x | blood, marrow, tissue
BCL-2 translocation | t(14;18) | | | x | x | x | x | blood, marrow, tissue
BCR/ABL gene rearrangement | Philadelphia chromosome | | | x | x | x | x | blood, marrow
Beta human chorionic gonadotropin | b-HCG | | | x | | x | x | serum
Beta-2 microglobulin | | | | x | x | | | serum
Bladder tumor antigen | BTA | | | | | x | x | urine
BRCA Analysis | BRCA1, BRCA2 | x | | | x | | | blood
Calcitonin | | | x | x | x | x | | serum
Cancer antigen 125 | CA 125 | | | | | x | x | serum
Cancer antigen 15-3 | CA 15-3 | | | | | x | x | serum
Cancer antigen 19-9 | CA 19-9 | | | | | x | x | serum
Cancer antigen 27.29 | CA 27.29 | | | | | x | x | serum
Carcinoembryonic antigen | CEA | | x | | x | x | x | serum
Cathepsin D | | | | | x | | | tissue
CBFB/MYH11 fusion protein | inv(16), t(16;16) | | | x | x | | x | blood, marrow
CD 117, c-kit | Gleevec sensitivity | | | x | | | | tissue
CD 20 | Rituxan sensitivity | | | x | | | | blood
CD 25 | Ontak sensitivity | | | x | | | | blood, marrow, tissue
CD 33 | Mylotarg sensitivity | | | x | | | | blood, marrow
CD 52 | Campath sensitivity | | | x | | | | blood, marrow
Chromosome 18q assay | 18q/RER, DCC | | | x | x | | | blood, tissue
Colaris | MLH1, MSH2 | | x | x | | | | blood
Colaris AP | APC, FAP | | x | x | | | | blood
Cyclin-D1 | | | | x | x | | | tissue
E-cadherin | | | | | x | | | tissue
Epidermal growth factor receptor | EGFR pharmDx, HER-1, Erbitux sensitivity | | | x | | | | tissue
Estrogen/progesterone receptor | ER/PR | | | x | x | | | tissue
Fecal globin | InSure, FOBT | | x | | | | | stool
FLT 3 mutation | | | | | x | | | blood
HER-2/neu | c-erbB-2, PathVysion, Herceptin eligibility | | | x | x | | | tissue
5-HIAA | 5-hydroxyindoleacetic acid | | | x | x | | | urine
Human papillomavius hybrid capture | HPV, ThinPrep | | x | | | | | pap smear
IgVH mutation analysis | | | | | x | | | blood, marrow
Immunocyt | mucin, CEA | | | | | x | x | urine
Kappa/lambda light chain | | | | | | | x | blood,tissue
LAP | leukocyte alkaline phosphatase | | | x | | | x | blood, marrow
Lipid associated sialic acid | LASA, LSA | | | | | x | x | serum
Melaris | p16 | x | | | | | | blood
MIB-1 antibody | Ki-67 antigen | | | | x | | | tissue
Micrometastasis detection | cytokeratins | | | | | x | x | marrow, tissue
Microsatellite instability | MSI, BAT-26, RER+, HNPCC | x | x | x | x | | | blood, tissue
MLH1, MSH2, MSH6 mutations | HNPCC mismatch repair gene | x | | | | | | blood
Neuron specific enolase | NSE | | | | | | x | serum
Nuclear matrix proteins | NMP 22 | | | x | | x | x | urine
Oncotype Dx | Breast cancer assay | | | | x | | | tissue
p53 tumor suppressor gene | p53 | | | | x | | | issue
PML/RARA translocation | t(15;17) | | | x | x | | x | blood, marrow
PreGen-26 | MSI, BAT-26 | x | x | | | | x | stool
PreGen-Plus | k-ras, APC, p53 | | x | | | | x | stool
Prostate-specific antigen | PSA free, total, ultrasensitive,HAMA | | x | | x | x | x | blood
T-cell recepter gene rearrangment | | | | x | | | | blood, marrow, tissue
TEL/AML1 gene fusion | t(12;21) | | | x | x | | x | blood, marrow
Thyroglobulin | | | | | | x | x | serum
Tumor antigen 90 immune complex | TA90-IC | | | | x | x | x | serum
Urokinase plasminogen activator | uPA, PAI-1(plasminogen activitor inhibitor) | | | | x | | | tissue
Urovysion | Vysis Urovysion | | | | | x | | urine
ZAP-70 | | | | | x | | | blood, marrow

NAME | Test type | Breast | Prostate | Lung | Colorectal | Pancreas | Ovarian | Esophagus | Liver | Lymphoma | Leukemia
Acid phosphatase, total and prostatic | ICMA,spectphoto | | x
Adrenocorticotropic hormone | ICMA | | | x | | x
Alpha fetoprotein | ICMA | | | x | x | x | | | x
AML1/ETO translocation | PCR | | | | | | | | | | x
B-cell gene rearrangement | PCR | | | | | | | | | x
BCL-1/JH gene rearrangement | PCR | | | | | | | | | x
BCL-2 translocation | PCR | | | | | | | | | x
BCR/ABL gene rearrangement | PCR, FISH | | | | | | | | | | x
Beta human chorionic gonadotropin | ICMA | | | x | | x | x | | x
Beta-2 microglobulin | ICMA | | | | | | | | | x
Bladder tumor antigen | cytology, EIA
BRCA Analysis | PCR | x | | | | x | x
Calcitonin | ICMA
Cancer antigen 125 | MEIA, ICMA | x | | x | x | x | x
Cancer antigen 15-3 | ICMA | x
Cancer antigen 19-9 | EIA | | | | x | x | | | x
Cancer antigen 27.29 | ICMA | x | | x | | x | x | | x
Carcinoembryonic antigen | ICMA | x | | x | x | x | x
Cathepsin D | IHC | x
CBFB/MYH11 fusion protein | PCR | | | | | | | | | | x
CD 117, c-kit | IHC
CD 20 | flow cytometry | | | | | | | | | x
CD 25 | IHC,flow cytometry | | | | | | | | | x
CD 33 | flow cytometry | | | | | | | | | | x
CD 52 | flow cytometry | | | | | | | | | | x
Chromosome 18q assay | PCR | | | | x
Colaris | PCR | | | | x
Colaris AP | PCR | | | | x
Cyclin-D1 | IHC | | | | | | | | | x
E-cadherin | IHC | | x
Epidermal growth factor receptor | IHC | x | x | x | x
Estrogen/progesterone receptor | IHC | x
Fecal globin | IHC | | | | x
FLT 3 mutation | PCR | | | | | | | | | | x
HER-2/neu | IHC,FISH,EIA | x | | | | | x
5-HIAA | liquid chromatography
Human papillomavius hybrid capture | DNA probe
IgVH mutation analysis | PCR | | | | | | | | | | x
Immunocyt | cytology, ICC
Kappa/lambda light chain | IHC | | | | | | | | | x
LAP | enzyme assay | | | | | x
Lipid associated sialic acid | spectrophotometry | x | | x | x | x | x | | x | x | x
Melaris | PCR | | | | | x
MIB-1 antibody | IHC | x | | | | | | | | x
Micrometastasis detection | IHC | x
Microsatellite instability | PCR | | | | x
MLH1, MSH2, MSH6 mutations | PCR | | | | x
Neuron specific enolase | RIA | | | x | | x
Nuclear matrix proteins | EIA
Oncotype Dx | PCR | x
p53 tumor suppressor gene | IHC | x | x | | x
PML/RARA translocation | PCR | | | | | | | | | | x
PreGen-26 | PCR | | | | x
PreGen-Plus | PCR | | | | x
Prostate-specific antigen | ICMA,IRMA,EIA | | x
T-cell recepter gene rearrangment | PCR | | | | | | | | | x
TEL/AML1 gene fusion | FISH | | | | | | | | | | x
Thyroglobulin | ICMA
Tumor antigen 90 immune complex | EIA
Urokinase plasminogen activator | EIA | x
Urovysion | FISH
ZAP-70 | flow cytometry | | | | | | | | | | x

NAME | Other cancers
Acid phosphatase, total and prostatic
Adrenocorticotropic hormone | carcinoid, thyroid, pituitary
Alpha fetoprotein | testicular germ cell cancer
AML1/ETO translocation | acute myelogenous leukemia
B-cell gene rearrangement | B-cell malignancies
BCL-1/JH gene rearrangement | mantle cell lymphoma
BCL-2 translocation | B-cell lymphomas
BCR/ABL gene rearrangement | chronic myelogenous leukemia, acute lymphoblastic leukemia
Beta human chorionic gonadotropin | testis, uterus, stomach
Beta-2 microglobulin | multiple myeloma, CLL and other indolent lymphomas
Bladder tumor antigen | bladder
BRCA Analysis
Calcitonin | medullary carcinoma of thyroid
Cancer antigen 125 | endometrial, cervical, primary peritoneal carcinoma
Cancer antigen 15-3
Cancer antigen 19-9 | gastric
Cancer antigen 27.29
Carcinoembryonic antigen
Cathepsin D
CBFB/MYH11 fusion protein | acute myelomonocytic leukemia (AML subtype M4E0)
CD 117, c-kit | gastrointestinal stromal tumors (GISTs): c-kit-positive
CD 20 | B-cell non-Hodgkin's lymphoma
CD 25 | cutaneous T-cell lymphoma
CD 33 | acute myeloid leukemia
CD 52 | chronic lymphocytic leukemia
Chromosome 18q assay
Colaris | hereditary non-polyposis colon (HNPCC), endometrial cancer
Colaris AP | familial adenomatous polyposis (FAP) associated cancer
Cyclin-D1 | mantle cell lymphoma
E-cadherin | prostate
Epidermal growth factor receptor | head and neck
Estrogen/progesterone receptor
Fecal globin
FLT 3 mutation | acute myelogenous leukemia
HER-2/neu
5-HIAA | carcinoid tumors
Human papillomavius hybrid capture | cervical cancer
IgVH mutation analysis | chronic lymphocytic leukema
Immunocyt | bladder cancer
Kappa/lambda light chain | multiple myeloma, lymphoproliferative disease
LAP | testicular germ cell cancer
Lipid associated sialic acid | melanoma, neuroblastoma, uterine, sarcoma
Melaris | melanoma
MIB-1 antibody | anaplastic large cell non-Hodgkin's lymphoma
Micrometastasis detection
Microsatellite instability | hereditary non-polyposis colon cancer
MLH1, MSH2, MSH6 mutations | hereditary non-polyposis colon cancer
Neuron specific enolase | melanoma, neuroblastoma, thyroid, neuroendocrine
Nuclear matrix proteins | bladder
Oncotype Dx
p53 tumor suppressor gene | bladder
PML/RARA translocation | acute promyelocytic leukemia (APL)
PreGen-26 | hereditary non-polyposis colon cancer
PreGen-Plus
Prostate-specific antigen
T-cell recepter gene rearrangment | T-cell malignancies
TEL/AML1 gene fusion | acute lymphoblastic leukemia
Thyroglobulin | thyroid carcinoma
Tumor antigen 90 immune complex | melanoma
Urokinase plasminogen activator
Urovysion | bladder cancer recurrence
ZAP-70 | chronic lymphocytic leukemia

NAME | Clinical use
Acid phosphatase, total and prostatic | monitor course of disease and treatment progress
Adrenocorticotropic hormone | diagnosis of ectopic ACTH syndrome seen in lung, pancreas, carcinoid, and thyroid tumors
Alpha fetoprotein | management of testicular cancer, monitor patients with hepatocellular cancer
AML1/ETO translocation | diagnosis of AML with t(8;21) translocation, monitor response to treatment, predict relapse
B-cell gene rearrangement | diagnosis of B-cell malignancies, determine prognosis and treatment, detect recurrence
BCL-1/JH gene rearrangement | diagnosis of mantle cell lymphoma, monitor minimal residual disease, predict relapse
BCL-2 translocation | diagnosis and characterization of lymphomas, detect residual disease
BCR/ABL gene rearrangement | diagnosis of CML and ALL, assess prognosis, monitor disease, predict relapse
Beta human chorionic gonadotropin | diagnosis of germ cell neoplasm, monitor for recurrence
Beta-2 microglobulin | may be useful for prognosis, monitor response to therapy, surrogate for disease activity
Bladder tumor antigen | monitor patient with history of bladder cancer
BRCA Analysis | screen for hereditary cancer in women already diagnosed with breast and ovarian cancer
Calcitonin | diagnosis and management of medullary carcinoma of the thyroid
Cancer antigen 125 | monitor ovarian cancer for residual disease and recurrence
Cancer antigen 15-3 | monitor patients with breast cancer
Cancer antigen 19-9 | monitor patients with pancreatic or gastrointestinal cancer
Cancer antigen 27.29 | monitor metastatic breast cancer patients, early detection of recurrence
Carcinoembryonic antigen | primarily used to monitor patients with colon cancer
Cathepsin D | predict survival in node negative breast cancer
CBFB/MYH11 fusion protein | diagnosis of AML with inv(16) or t(16;16)(ie CBFB/MYH11)
CD 117, c-kit | determine eligibility for Gleevec (imatinib mesylate)
CD 20 | determine eligibility for Rituxan (rituximab, anti-CD20)
CD 25 | determine eligibility for Ontak (denileukin diftitox, anti CD25)
CD 33 | determine eligibility for Mylotarg (anti-CD33, semtuzumab ozogamicin)
CD 52 | determine eligibility for Campath (alemtuzumab, anti-CD52) in patients with CLL
Chromosome 18q assay | determine prognosis, guide therapy
Colaris | genetic susceptibility test for HNPCC and endometrial cancer
Colaris AP | genetic susceptibility test for FAP-associated cancer
Cyclin-D1 | used for diagnosis of mantle cell lymphoma
E-cadherin | prognostic assessment for prostate cancer
Epidermal growth factor receptor | determine eligibility for Erbitux (cetuximab, EGFR inhibitor) for colorectal cancer, breast cancer prognosis
Estrogen/progesterone receptor | determine prognosis in breast cancer, predict response to hormonal therapy
Fecal globin | screen for lower gastrointestinal bleeding associated with colorectal cancer and other conditions
FLT 3 mutation | prognostic information for AML
HER-2/neu | determine eligibility for Herceptin, assess prognosis, predict survival in chemotherapy patients
5-HIAA | monitor patients with carcinoid tumors
Human papillomavius hybrid capture | assess cervical cancer risk
IgVH mutation analysis | assess prognosis for CLL
Immunocyt | early detection and management of bladder cancer
Kappa/lambda light chain | monitor disease activity
LAP | help determine disease prognosis
Lipid associated sialic acid | monitor tumor burden in a variety of malignacies, including Hodgkin's, leukemia, melanoma
Melaris | screen for hereditary melanoma
MIB-1 antibody | predict survival breast cancer, diagnosis of anaplastic NHL, assess tumor cell proliferation
Micrometastasis detection | detect micrometastases of epithelial cell origin, predict recurrence, survival
Microsatellite instability | monitor HNPCC patients, assess need to test relatives for HNPCC
MLH1, MSH2, MSH6 mutations | differentiate HNPCC from non-HNPCC, assess risk of family members
Neuron specific enolase | monitor disease in small cell lung cancer, also elevated in neuroblastoma, pancreatic, thyroid, others
Nuclear matrix proteins | diagnosis of bladder cancer, monitor for recurrence
Oncotype Dx | predict likelihood of recurrent disease in early stage breast cancer patients
p53 tumor suppressor gene | prognostic marker for prostate cancer and other tumor
PML/RARA translocation | diagnosis of APL, predict response to all trans retinoic acid (ATRA)
PreGen-26 | used as adjunct to colonoscopy for monitoring HNPCC
PreGen-Plus | enhance detection of colorectal cancer
Prostate-specific antigen | screening, diagnosis, management of prostate cancer, detect residual and recurrent disease
T-cell recepter gene rearrangment | diagnosis of T-cell malignancies, detect minimal residual disease or recurrence
TEL/AML1 gene fusion | diagnosis, prognosis, monitor ALL patients
Thyroglobulin | detect presence of residual papillary-follicular carcinoma of thyroid
Tumor antigen 90 immune complex | assess prognosis for malignant melanoma, monitor for recurrence
Urokinase plasminogen activator | assess risk of recurrence, assess need for therapy, predict teatment response
Urovysion | detect bladder cancer recurrence
ZAP-70 | assess prognosis and need for aggressive treatment in CLL