# REFERENCES

1 Secretary's Advisory Committee on Genetic Testing. Department of Health and Human Services. Request for public comment on a proposed classification methodology for determining level of review for genetic tests. Federal Register. 76643. 2000;(236):65-76645.
2 New frontiers in grey literature: GL'99 proceedings. Fourth International Conference on Grey Literature. Washington, D.C. GreyNet. 1999.
3 Alberani V, De Castro Pietrangeli P, Mazza AM. The use of grey literature in health sciences: a preliminary survey. Bull Med Libr Assoc. 1990;78:358-363. [pmid: 2224298].
4 Baker M. In biomarkers we trust?. Nat Biotechnol. 2005;23:297-304. [pmid: 15765081].
5 NLM. National Library of Medicine's Health Technology Assessment Information Resources. 2005. http://www.nlm.nih.gov/nichsr/ehta/chapter10.htm.
6 NCI. The Early Detection Research Network: Translational Research to Identify Early Cancer and Cancer Risk. 2005. Third Report.