# APPENDIX

A1 Glossary of acronyms used

A2 Synopsis of select commercial diagnostic laboratories (information from company websites)

A3 Additional companies and websites

A4 Exploratory Medline search strategy: genetic tests for 10 cancers

A5 Sample titles from searches of the grey literature databases