# RESULTS

## Study selection and evaluation

Overall we identified 6,345 citations from electronic databases (n=6,207), reference lists (n=45), and the Centers for Medicare and Medicaid Services (n=93). We reviewed 254 full manuscripts for potential inclusion. We excluded 196 of these studies after detailed evaluation; the reasons for exclusion are detailed in Figure 1 and Appendix A (a full list of excluded studies is included in Appendix B).

Figure 1 Flow of trials through the selection process

Studies screened for possible inclusion (n=6345) Full manuscripts reviewed for inclusion (n=254) Trial publications potentially relevant to the review (n=58) Total number of unique trials relevant to the review (n=46) Studies excluded (n=196): • Not randomized (n=54) • Single modality intervention (n=25) • Primary prevention (n=16) • Guideline or review article (n=24) • Did not report outcomes (n=11) • Abstract only (n=10) • Drug interventions (n=8) • Data not separate for CAD pts (n=7) • Protocol only (n=5) • Population not CAD (n=6) • No usual care arm (n=5) • Non-English (n=2) • Inpatient-based intervention (n=2) • Methodological flaws (n=1) • Summary of article already included (n=1) • Duplicate (n=1) • Self-directed intervention (n=1) • Exercise only (n=17)

Disagreement among the reviewers regarding eligibility of the studies occurred on 16 occasions for a kappa value of 0.81. All disagreements were resolved by consensus.

Of the randomized trials eligible for inclusion,[28–85] 9 were reported in more than one publication. Two trials reported different endpoints in two separate publications.[28,29,57,58] One trial[30] reported the outcomes for all patients enrolled (only 56% of whom had cardiac disease) and, in a separate publication[31], provided details of event rates in the subgroup of patients with cardiac disease. The WHO Trial[32] included 24 collaborating centers; however, the original investigators excluded 7 sites because of poor subject follow-up, and 4 sites due to significant differences at baseline between the intervention and control arms. We included the 3-year outcome data from the remaining 13 sites as one trial for the purposes of this analysis, an approach validated by the non-significant tests for statistical heterogeneity for all-cause mortality (Q=15.7, 11 df, p=0.16) and MI (Q=15.9, 11 df, p=0.15) and the fact that the summary risk ratios for both endpoints were identical under the random and fixed effects models. While the two Finnish centers in the WHO Trial published their results separately (and for multiple follow-up periods), we included only their 3-year outcome data with the other 11 WHO sites for consistency of data presentation.[33–35] In five cases, we identified studies that reported longer follow-up data from another relevant trial.[36–40]

## Studies included in the systematic review

Summary data from the 46 unique randomized trials eligible for this systematic review are presented in Table 1.[28–85] In all of the trials, patients randomized to the control groups received usual care (which was generally undefined). One trial [41] is presented twice in Table 1 because it had two intervention groups (comprehensive cardiac rehabilitation and group counseling) as well as a usual care control arm. Although all of the control patients were included for the subgroup analyses in which this trial was relevant (comprehensive cardiac rehabilitation versus usual care, and group cardiac rehabilitations versus usual care), for the overall analyses (in which all 3 types of secondary prevention programs in the 46 trials were pooled, we only included the control arm patients once).

Table 1 Description of studies included

Study | Sample Size | Study Population (Location) | Mean Age | % Male | Key Components of Intervention | Duration of Intervention
Comprehensive Cardiac Rehabilitation (19 trials, 4208 patients)
Sivarajan et al. (1982) | 258 (170 in control and comprehensive secondary prevention arms) | Patients younger than 70 years discharged after AMI (USA) | 57 | >80% | Exercise program plus group education/counseling sessions about risk factor management | 3 m
Vermeulen et al. (1983) | 98 | Males 40–55 yrs, discharged after AMI (Netherlands) | 49 | 100% | Multidisciplinary team (details not given) involved in exercise rehabilitation, social and psychological supports for patients | 1.5–2 m
Bengtsson (1983) | 87 | Patients aged <65 years, one year after AMI (Sweden) | 56 | 85% | Rehabilitation program involving physical assessment and training by physiotherapy and counseling | 3 m
World Health Organization^*^ (1983) | 1,735 | Males < 65 yrs, discharged after AMI (Europe) | 53 | 100% | Multidisciplinary team (components differed at each center) involved in patient health education and supervised exercise program | 36 m
Ornish et al. (1990) with longer term f/u reported in Ornish et al. (1998) | 28 | Patients 35–75 yrs with confirmed CAD at least 6 weeks after cardiac event (USA) | 58 | 84% | One week residential program followed by 2 × weekly support meetings relating to low-fat vegetarian diet, stress management, exercise and social support | 12 m/60 m
Oldridge et al. (1991) | 201 | Patients discharged with diagnosis of AMI and evidence of anxiety or depression (Canada) | 52 | 89% | Exercise prescription, supervised training and behavioral counseling | 2 m
PRECOR (1991) | 182 | Males <65 years, discharged after AMI (France) | 51 | 100% | Two intervention arms, one of which was: Comprehensive cardiac rehabilitation (supervised exercise program, relaxation training, risk factor management, education) | 1.5 m
Fridlund et al. (1991) | 178 | Patients <65 years discharged after AMI (Sweden) | 56 | 87% | Nurse-led rehabilitation program addressing lifestyle, stress and social support. | 6m
Engblom et al. (1992) | 228 | Patients younger than 65 years, discharged after CABG (Finland) | 54 | 88% | Group education, individual counseling (with physician and dietician) about diet and physical activity, supervised exercise training | 0.75 m
Heidelberg Trial (Schuler et al. 1992 and Niebauer et al. 1997) | 113 | Males with CAD on angiography (Germany) | 54 | 100% | Education about diet and exercise, exercise program with individual and group training sessions | 12 m
Bell (1998) | 353 (201 in control and comprehensive secondary prevention arms) | Patients ≤ 75 years discharged after AMI (UK) | 60 | 78% | Comprehensive cardiac rehabilitation (supervised exercise program, group education sessions on risk factor management) | 3 m
Johnston et al. (1999) | 100 | Patients ≤ 70 years hospitalized for 1^st^ time myocardial infarction (UK) | 56 | 65% | Nurse-led inpatient and outpatient cardiac rehabilitation program containing education, support for risk factor change and psychological effects. | 1.5 m
Lisspers et al. (1999) | 93 | Patients <65 after PCI (Sweden) | 53 | 37% | Comprehensive residential (health education, behavioral change) containing skills training, habit rehearsal on stress management, smoking, diet, exercise and smoking; followed by outpatient program of self observation and reporting of risk factors with follow up support. | 12 m
Toobert et al. (2000) | 28 | Post menopausal female patients with documented CAD at least 6 weeks after cardiac event | 64 | 0% | Residential program for women and spouse including support for low fat cookery, stress management, supervised exercise, and peer support sessions; followed by 2 × weekly community sessions. | 9 m
Seki et al. (2003) | 38 | Male patients (>65 years) with CAD referred to hospital within past 6 months after MI, CABG or PTCA (Japan) | 70 | 100% | Out patient program including supervised exercise sessions, and prescription, dietary and educational components. | 6 m
Sundin et al. (2003) | 132 | Male patients <70 years after PCI, AMI or CABG (Sweden) | 59 | 100% | Group-based multidisciplinary program addressing stress management, diet and exercise using lectures and skills training | 12 m
Yu et al. (2003) | 112 | Obese patients attending cardiac rehabilitation after acute MI or after percutaneous coronary intervention (China) | 62 | 79% | Exercise program with group education classes about risk factor modification | 2.5 m
Vestfold Heartcare Study (2003) | 197 | Patients discharged after acute coronary syndrome, CABG, PCI (85%); plus patients followed in clinic with stable CAD (15%) (Norway) | 55 | 82% | Supervised exercise program, dietary advice, risk factor management education and individual plus group counseling involving a multidisciplinary team (physician, nurse, dietician, physiotherapist) | 24 m
Marchionni et al. (2003) | 270 | Patients older than 45 years discharged after AMI (Italy) | 69 | 71% | Supervised exercise training and education/counseling about risk factor management, optional monthly support groups | 2 m
Group Cardiac Rehabilitation without exercise component (4 trials, 2671 patients)
Stern et al. (1983) | 106 (64 in control and group counseling arms) | Patients aged 30–69 years with recent MI (USA) | 54 | 83% | Nurse and psychiatrist/social worker led group education and counseling sessions (12 sessions) | 3 m
PRECOR (1991) | 182 | Males <65 years, discharged after AMI (France) | 51 | 100% | Two intervention arms, one of which was: Group Counseling Program (group education and counseling led by physician, psychiatrist, and nutritionist) | 1.5 m
Jones & West (1996) | 2328 | Patients discharged home within 28 days of AMI (United Kingdom) | 62 | 73% | Nurse and psychologist regularly saw participants for education, counseling, and relaxation/stress management training | 1.75 m
DIET (Masley et al. 2001) | 97 | Patients with known CAD and hyperlipidemia in specialty clinics (USA) | 65 | 70% | Nurse-led education (group) and provision of written materials about diet and physical activity | 12 m
Individual Counseling (24 trials, 11 942 patients)
Ornish et al. (1983) | 23 | Patients 45–75 yrs with evidence of CAD as documented in hospital records (USA) | 59 | 78% | Residential program in remote rural location of stress management and low fat dietary meals and training | 1 m
SCRIP (Haskell et al. 1994) | 300 | Patients < 75 yrs referred for angiography for known or suspected CAD (USA) | 56 | 86% | Nurse-managed patient education and algorithm-driven management of risk factors, exercise program, frequent telephone and clinic visits with nurse | 48 m
DeBusk et al. (1994) and Taylor et al. (1997) | 585 | Patients ≤ 70 yrs discharged after AMI (USA) | 57 | 79% | Nurse-managed patient education and counseling, exercise program, frequent telephone contact, and algorithm-based lipid therapy | 12 m
Fitzgerald et al. (1994) | 668 | Patients > 45 yrs discharged from a general medicine in-patient service (2/3 with heart disease) and being followed at the general medicine clinic of a Veterans Affairs hospital (USA) | 65 | 100% | Nurse-managed patient education, coordination of care, frequent telephone contact, and protocol-driven systematic assessments for unmet socio-medical needs | 12 m
Naylor et al. (1994) | 276 (142 with cardiac disease) | Patients > 70 yrs discharged from a tertiary care hospital with either CAD or heart failure (USA) | 76 | 49% | Comprehensive discharge planning protocol with gerontologic nurse providing education, coordinating care, and maintaining telephone contact for 2 weeks | 0.5 m
Cupples and McKnight (1994 and 99) | 688 | Patients <75 years with angina for at least 6 months identified from general practice records (UK) | 63 | 59% | Individual nurse-led personalized health promotion program every 4 months | 24 m
M-HART (Frasure-Smith et al. 1997) | 1376 | Patients discharged after AMI (Canada) | 59 | 66% | Nurse contacted patients monthly by telephone, providing education and advice and screening patients for psychological distress- nurses referred patients to other health care resources as needed | 12 m
Carlsson et al (1997) | 168 | Patients aged 50–70 years discharged after AMI (Sweden) | 62 | 75% | Nurse-run education program (individual and group), exercise training program, nurse clinic visits | 12 m
Carlsson (1998) | 530 | Patients aged 50–70 years discharged after AMI, CABG or PCI (Sweden) | 62 | 79% | Individualized assessment and nurse counseling on risk factors and diet | 12 m
Campbell et al. (1998), with longer term f/u reported in Murchie et al (2003) | 1343 | Patients <80 yrs old with documented CAD recruited from general practice records (United Kingdom) | 66 | 58% | Regular follow-up at secondary prevention clinics run by nurses, promoting medical and lifestyle approaches to prevention | 12 m
Jolly et al. (1999) | 597 | Patients with AMI or recent onset angina discharged from hospital or seen in a chest pain clinic (United Kingdom) | 64 | 71% | Cardiac liaison nurse coordinated care between discharging service and family physician, patients given personal health record and prompts for follow-up | 12 m
Naylor and McCauley (1999) | 363 (202 with cardiac disease) | Patients ≥ 65 years discharged from a tertiary care hospital with either CAD or heart failure or after CABG/heart surgery (USA) | 75 | 50% | Nurse-led patient education, coordination of home care, at least 2 home visits, use of a standardized protocol to optimize medications, and weekly telephone contact for 1 month | 1 m
Allison et al. (1999) | 152 | Patients not treated with lipid lowering medication that completed cardiac rehabilitation after an acute coronary event (USA) | 64 | 82% | Nurse-led follow up program every 6 weeks after start or change in lipid lowering therapy, including diet and exercise advice and lipid lowering medications. | 6 m
Allison et al. (2000) | 326 | Patients attending emergency room with confirmed unstable angina (USA) | 58 | 56% | Nurse-intervention including lipid management, referral to support services, counseling on risk factors and physician collaboration on abnormal results, 2 1-hour sessions at least 6 and 25 days after discharge | 1 m
Moher et al. (2001) | 1906 | Patients 55–75 years identified in family practices with established CAD (UK) | 66 | 68% | Nurse-led clinic providing support for risk factor change using electronic disease register and recall system | 1 m
Stagmo et al. (2001) | 241 | Patients 50–69 years hospitalized in a CCU due to MI or previous CABG (Sweden) | 62 | 78% | Hospital-based secondary prevention program | 12 m
McHugh et al. (2001) | 98 | Patients on a waiting-list for elective CABG (UK) | 62 | 76% | Shared nurse-led care program of monthly health education and motivational interviewing | 7 m
Higgins et al. (2001) | 105 | Patients discharged after PCI (Australia) | 48 | 90% | Nurse-led individualized education, risk factor goal setting and self-monitoring with telephone feedback, 3 home visits | 12 m
Allen et al. (2002) | 228 | Patients ≤ 75 years discharged after CABG or PCI who had hypercholesterolemia (USA) | 60 | 63% | Nurse practitioner case management in partnership with patient’s primary provider (nurse-directed education and lifestyle modification advice, nurse clinic visits, nurse prescribed medications if necessary, f/u telephone calls) | 12 m
COACH pilot (Vale et al. 2002) | 245 | Patients ≤ 75 years discharged after coronary revascularization procedure (Australia) | 61 | 75% | Personal coaching by dietician via 5 telephone sessions and 5 mailings to achieve coronary risk factor targets (education, negotiated lifestyle plan, emphasis on follow-up with primary care provider and empowerment to ask for medication, repeated measurements) | 6 m
COACH (Vale et al. 2003) | 792 | Patients discharged from 6 hospitals after CABG, PCI, AMI, coronary angiography (Australia) | 59 | 77% | Personal coaching (delivered by nurses or dieticians) via 5 telephone sessions and 5 mailings to achieve coronary risk factor targets (education, negotiated lifestyle plan, emphasis on follow-up with primary care provider and empowerment to ask for medication, repeated measurements) | 6 m
ELMI Trial (Lear et al. 2003) | 302 | Patients discharged from 2 tertiary-care cardiac rehabilitation programs (Canada) | 64 | 83% | Personal coaching by case manager delivered via telephone and in-person counseling sessions; if suboptimal coronary risk factors at 6 months, treatment algorithms with cover letter from cardiologist mailed to primary care physicians | 12 m
Young et al .(2003) | 146 | Patients discharged home after AMI (Canada) | 69 | 60% | Patient education, at least 6 home visits by nurse, nurse communication with primary care providers, and nurse-initiated referral for specialty care (based on standardized pathway) | 2 m
REACH Trial (Lichtman et al. 2004) | 756 | Patients aged 30–80 years discharged from tertiary care hospital with documented coronary disease (USA) | 64 | 71% | Nurse-based education and counseling about cholesterol and target levels delivered via telephone (4 calls in 9 m) and mailed educational materials about a variety of secondary prevention maneuvers | 12 m

* As outlined in text, the results for 13 of the 24 collaborating centers in the World Health Organization Trial are included here. Reasons for the exclusion of the other 11 centers are given in the text.

CABG = coronary artery bypass grafting; CAD = coronary artery disease; COACH = Coaching patients On Achieving Cardiovascular Health Study; DIET = Dietary Intervention and Evaluation Trial; ELMI = Extensive Lifestyle Management Intervention ; ETICA = Exercise Training Intervention after Coronary Angioplasty; M-HART = Montreal Heart Attack Readjustment Trial; MI = myocardial infarction; NEHDP = National Exercise and Heart Disease Project; NR = not reported; PCI = percutaneous coronary intervention; CCU = coronary care unit; REACH= Reinforcing Education About Cholesterol; SCRIP = Stanford Coronary Risk Intervention Project; UK = United Kingdom; USA = United States.

Our search retrieved 34 trials not included in our previous systematic review (that was limited to the pre-1999 literature)[25] and 26 trials not included in a more recent systematic review of cardiac rehabilitation (that was based on an earlier Cochrane review and limited to the pre-2003 literature on exercise interventions)[22,23].

## Quantitative data synthesis

All-cause mortality: Only one of the 29 trials reporting this outcome found a statistically significant survival benefit with the intervention (Table 2, Figures 2–4). The summary RR for all 29 trials reporting all-cause mortality (13 857 patients) was 0.87 (95% CI 0.79–0.97), using the data from the entire follow-up period in each trial (which ranged from 6 months to 6 years), with no significant statistical heterogeneity between trials (p=0.95, I-squared=0%). Pooling the data at the 12 month follow-up visit in each trial (or as close to 12 months as possible), the summary RR for all 29 trials was 0.90 (95% CI 0.79–1.01), with no significant statistical heterogeneity between trials (p=0.90, I-squared=0%).

Table 2 Impact of interventions on all-cause mortality and recurrent myocardial infarctions

Study | Length of Follow-up | All-cause mortality (#events/total # patients) | | | Recurrent Myocardial Infarctions^*^ (#events/total # patients)
Study | Length of Follow-up
Study | Length of Follow-up | Intervention Arm | Control Arm | Risk Ratio | Intervention Arm | Control Arm | Risk Ratio
Comprehensive Cardiac Rehabilitation
Sivarajan et al. | 6 m | 3/86 | 2/84 | 1.47 (0.25, 8.55) | NR | NR | NR
Vermeulen et al. | 60 m | 2/47 | 5/51 | 0.43 (0.09, 2.13) | 4/47 | 9/51 | 0.48 (0.16, 1.46)
Bengtsson | 12 m | 10/81 | 6/90 | 1.85 (0.70, 4.87) | 2/81 | 4/90 | 0.56 (0.10, 2.95)
WHO | 36 m | 146/893 | 161/842 | 0.86 (0.70, 1.05) | 150/893 | 139/842 | 1.02 (0.82, 1.26)
Ornish et al. (90,98) | 60m | 2/28 | 1/20 | 1.43 (0.14, 14.70) | 25/28 | 45/20 | 0.36 (0.07, 1.76)
Oldridge et al. | 12 m | 3/99 | 4/102 | 0.77 (0.18, 3.36) | NR | NR | NR
PRECOR^**^ - comprehensive rehabilitation arm | 24 m | 0/60 | 4/61 | 0.11 (0.01, 2.05) | 4/60 | 6/61 | 0.68 (0.20, 2.28)
Fridlund et al. | 12 m | 9/87 | 14/91 | 0.67 (0.31, 1.47) | 4/87 | 14/91 | 0.30 (0.10, 0.87)
Engblom et al. | 12 m | 12/119 | 13/109 | 0.85 (0.40, 1.77) | 8/119 | 16/109 | 0.46 (0.20, 1.03)
Heidelberg Trial | 12 m | 2/56 | 1/57 | 2.04 (0.19, 21.82) | 2/56 | 4/57 | 0.51 (0.10, 2.67)
Heidelberg Trial | 72 m | 5/43 | 8/53 | 0.77 (0.27, 2.18) | 3/43 | 4/53 | 0.92 (0.22, 3.91)
Bell | 12 m | 7/99 | 8/102 | 0.90 (0.34, 2.39) | NR | NR | NR
Lisspers et al. | 12 m | 0/46 | 1/41 | 0.30 (0.01, 7.12) | NR | NR | NR
Vestfold Heartcare Study | 24 m | 2/98 | 1/99 | 2.02 (0.19, 21.92) | 4/99 | 3/99 | 1.33 (0.72, 1.05)
Marchionni et al. | 12 m | 7/180 | 3/90 | 1.17 (0.31, 4.41) | 1/180 | 3/90 | 0.17 (0.02, 1.58)
Sub-Total: | 14 trials | 208/1966 | 231/1835 | 0.86 (0.73, 1.03) | 182/1637 | 202/1506 | 0.64 (0.43, 0.95)
Group Cardiac Rehabilitation without exercise component
Stern et al. | 12 m | 0/35 | 1/29 | 0.28 (0.01, 6.57) | 3/35 | 2/29 | 1.24 (0.22, 6.94)
PRECOR^**^ -counseling arm | 24 m | 5/61 | 4/61 | 1.25 (0.35, 4.43) | 4/61 | 6/61 | 0.67 (0.20, 2.25)
Jones & West | 12 m | 79/1168 | 84/1160 | 0.93 (0.69, 1.26) | 43/1168 | 48/1160 | 0.89 (0.59, 1.33)
Sub-Total: | 3 trials | 84/1264 | 89/1250 | 0.94 (0.70, 1.25) | 50/1264 | 56/1250 | 0.88 (0.61, 1.28)
Individual Counselling
SCRIP | 12 m | 1/145 | 0/155 | 3.21 (0.13, 78.06) | 5/145 | 0/155 | 11.75 (0.66, 210.69)
SCRIP | 24 m | 1/145 | 2/155 | 0.53 (0.05, 5.83) | 5/145 | 3/155 | 1.78 (0.43, 7.32)
SCRIP | 36 m | 2/145 | 2/155 | 1.07 (0.15, 7.49) | 5/145 | 6/155 | 0.89 (0.28, 2.86)
SCRIP | 48 m | 3/145 | 3/155 | 1.07 (0.22, 5.21) | 6/145 | 11/155 | 0.58 (0.22, 1.54)
DeBusk et al. and Taylor et al. (1997) | 12 m | 12/293 | 10/292 | 1.20 (0.52, 2.72) | 10/293 | 20/292 | 0.50 (0.24, 1.05)
Fitzgerald et al. | 12 m | 35/333 | 35/335 | 1.01 (0.65, 1.57) | NR | NR | NR
Cupples & McKnight | 24 m | 13/342 | 29/346 | 0.45 (0.24, 0.86) | NR | NR | NR
Cupples & McKnight | 60 m | 47/342 | 65/346 | 0.73 (0.52, 1.03) | NR | NR | NR
M-HART | 12 m | 38/692 | 27/684 | 1.39 (0.86, 2.25) | 44/692 | 42/684 | 1.04 (0.69, 1.56)
Carlsson (1998) | 12 m | 2/118 | 2/117 | 0.99 (0.14, 6.92) | NR | NR | NR
Campbell et al. | 12 m | 22/673 | 25/670 | 0.88 (0.50, 1.54) | 13/540 | 12/518 | 1.04 (0.48, 2.26)
Campbell et al. | 56 m | 100/673 | 128/670 | 0.78 (0.61, 0.99) | 100/673 | 125/670 | 0.80 (0.63, 1.01)
Jolly et al. | 12 m | 15/277 | 23/320 | 0.75 (0.40, 1.42) | NR | NR | NR
Allison et al. (2000) | 6m | 2/158 | 2/168 | 1.06 (0.15, 7.46) | 0/158 | 1/168 | 0.35 (0.01, 8.63)
COACH pilot | 6 m | 0/121 | 2/124 | 0.20 (0.01, 4.22) | NR | NR | NR
COACH | 6 m | 4/398 | 4/394 | 0.99 (0.25, 3.93) | NR | NR | NR
COACH | 48 m | 32/398 | 32/394 | | NR | NR | NR
ELMI | 12 m | 1/151 | 3/151 | 0.33 (0.04, 3.17) | NR | NR | NR
Young et al. | 14 m | 8/71 | 11/75 | 0.77 (0.33, 1.80) | NR | NR | NR
Sub-Total: | 13 trials | 295/3772 | 343/3831 | 0.86 (0.75, 1.00) | 160/1961 | 199/1969 | 0.81 (0.66, 0.98)
TOTAL | 29 trials **
-closest to 12m data | | 442/7015 | 482/6859 | 0.90 (0.79, 1.01) | 303/4742 | 327/4516 | 0.80 (0.65, 0.99)
-over entire study | | 587/7002 | 659/6855 | 0.87 (0.79, 0.97) | 392/4862 | 451/4664 | 0.83 (0.72, 0.96)

For trials with outcomes reported at various timepoints, the longest duration of follow-up data was used for generating the pooled sub-total estimates. The pooled total estimates are presented for both the “12 month or closest to 12 month data” as well as “longest duration of follow-up in each trial”. NR= not reported

* Data for all trials except that of Campbell et al., DeBusk et al., and Allison et al. are for the combined endpoint of nonfatal and fatal myocardial infarction. The Campbell et al. trial only collected data on nonfatal reinfarction rate and total mortality (they were unable to dissect out causes of mortality). The Allison et al. and DeBusk et al. trials collected data on nonfatal myocardial infarction.

** Note that for PRECOR, there were 2 intervention arms and 1 control arm. The control arm data has been included only once in the “TOTAL” pooled estimate.

Figure 2 All-cause mortality in trials evaluating comprehensive cardiac rehabilitation

Figure 2

Figure 3 All-cause mortality in trials evaluating group cardiac rehabilitation without exercise component

Figure 3

Figure 4 All-cause mortality in trials evaluating individual counseling

Figure 4

Although there was no appreciable difference in the treatment effects with any of the 3 types of secondary prevention programs (Table 2, Figures 2–4), there were differences in effect over time. While the RR for all-cause mortality was 0.97 (95% CI 0.82–1.14) in the 19 trials (9393 patients, p for heterogeneity=0.95, I-squared=0%) reporting 12 month outcome data, the RR for all-cause mortality was 0.53 (95% CI 0.31–0.92) in the 4 trials (1367 patients, p for heterogeneity=0.44, I-squared=0%)[40,41,43,77] reporting 24 month outcome data. Furthermore, pooling the data from the 5 trials (2273 patients)[28,39,40,42,71,72] reporting follow-up data from at least 5 years after initiation of the intervention program demonstrates that programs had a sustained beneficial effect: the RR for all-cause mortality was 0.76 (95% CI 0.62–0.92) at 5 years with no appreciable heterogeneity between the trials (p=0.93, I-squared=0%).

Re-infarction Rate: One of the 17 trials reporting this endpoint (Table 2, Figures 5–7) detected a significant difference between intervention and control patients and the summary RR for re-infarction rate at longest follow up for all 9526 patients was 0.83 (95% CI 0.72–0.96) with no significant heterogeneity (p=0.39, I-squared=6%). At 12 months, or as close as possible to 12 months, (17 trials, n=9258), the RR of re-infarction was 0.80 (95% CI 0.65–0.99) in patients randomized to secondary prevention programs. There was no significant statistical heterogeneity among trials at 12 months (p=0.24, I-squared=18%). There was no appreciable difference in the treatment effects with any of the 3 types of secondary prevention programs (Table 2, Figures 5–7), neither were there any differences in effect over time.

Figure 5 Recurrent myocardial infarctions in trials evaluating comprehensive cardiac rehabilitation

Figure 5

Figure 6 Recurrent myocardial infarctions in trials evaluating group cardiac rehabilitation without exercise component

Figure 6

Figure 7 Recurrent myocardial infarctions in trials evaluating individual counseling

Figure 7: Recurrent myocardial infarctions in trials evaluating individual counseling

Hospitalization Rate: Two of the 13 trials (5751 patients) reporting hospitalization rates detected a significant difference between intervention and control patients. The summary random effects RR for hospitalization rates for all 5751 patients was 0.85 (95% CI 0.78–0.93)- (Figure 8). There was no significant statistical heterogeneity between trials (p=0.24, I-squared=20%) despite the fact that some trials reported data on all-cause hospitalizations and some on only cardiovascular hospitalizations. Median length of follow-up in these trials was approximately 12 months.

Figure 8 Hospitalization rates in trials evaluating secondary prevention programs

These data depict risk ratios for the number of patients requiring at least one hospitalization during follow-up. RR<1 are consistent with less hospitalizations in the intervention arm; RR>1 are associated with less hospitalizations in the control arm. Note that the data from some studies (SCRIP, Heidelberg, M-HART, Allison, and COACH) are “cardiovascular hospitalizations” while for the other studies it is “all-cause hospitalizations”. The “all-cause hospitalization” summary RR was 0.84 (95% CI 0.74–0.97) in 9 trials (n=3653) and the “cardiovascular hospitalization” summary RR was 0.76 (95% CI 0.58–0.98) in 7 studies (n=3233).

Figure 8

Restricting our analysis to the 9 trials (3653 patients) which reported all-cause hospitalization rates revealed a summary random effects RR of 0.84 (95% CI 0.74–0.97). Restricting our analysis to the 7 trials (3233 patients) which reported cardiovascular hospitalization rates revealed a summary random effects RR of 0.76 (95% CI 0.58–0.98).

Sensitivity Analyses: Analyses failed to reveal any effect of publication year on the observed results (data not shown).

Publication Bias: There was no evidence of publication bias (see Funnel Plot in Figure 9 for our primary outcome of all-cause mortality). The results of Begg’s Test (p=0.41) and Egger’s Test (p=0.88) confirm this.

Figure 9 Funnel Plot for all-cause mortality data

Figure 9

Processes of Care: Twenty-seven trials tested the impact of these disease management programs on cardiovascular risk factors. Twenty two demonstrated better cholesterol profiles in patients randomized to the interventions, although the differences were statistically significant in only 14 trials and the effect sizes were generally small to moderate (Table 3). Of the 20 trials that assessed the use of proven efficacious medications, 8 demonstrated statistically significantly better application of at least one of these therapies in the intervention patients, 2 demonstrated better prescribing in intervention patients but did not achieve statistical significance, and 10 failed to demonstrate any appreciable difference between intervention and control patients (Table 3). It should be noted that in many cases the failure to demonstrate improved processes of care with the intervention was because of improved risk factor management in control patients. For example, in one study that followed patients for over 4 years, 55% of controls had been exposed to comprehensive secondary prevention clinics by the close of the study.[37]

Table 3 Impact of interventions on other endpoints

Study | Major Cardiovascular Risk Factors | | | Use of proven efficacious therapies | Patient Quality of Life | Patient functional status or symptom scores
Study | | | | Use of proven efficacious therapies | Patient Quality of Life | Patient functional status or symptom scores
Study | Cholesterol | Smoking | BP | Use of proven efficacious therapies | Patient Quality of Life | Patient functional status or symptom scores
Comprehensive Cardiac Rehabilitation
Sivarajan et al. | NR | NR | NR | NR | NR | NR
Vermeulen et al. | ++ | 0 | NR | NR | NR | +
Bengtsson | NR | NR | ++ | NR | 0 | NR
WHO^*^ | ++ | - | ++ | ++ | NR | 0
Ornish et al. (90, 98) | ++ | NR | 0 | NR | NR | ++
Oldridge et al. | NR | NR | NR | NR | + | 0
PRECOR - comprehensive rehabilitation arm | NR | 0 | NR | NR | NR | ++
Fridlund et al. | NR | 0 | NR | NR | ++ | ++
Engblom et al. | 0 | ++ | 0 | 0 | ++ | NR
Heidelberg Trial
−12 m f/u | ++ | 0 | NR | 0 | NR | NR
−72 m f/u | 0 | 0 | NR | 0 | NR | NR
Johnston et al. | NR | NR | NR | NR | ++ | ++
Lisspers et al. | NR | ++ | NR | NR | NR | NR
Toobert et al. | 0 | + | + | NR | ++ | ++
Seki et. al. | NR | NR | NR | NR | ++ | 0
Sundin et al. | + | NR | NR | NR | NR | NR
Yu et al. | NR | NR | NR | NR | + | +
Vestfold Heartcare Study | 0 | ++ | 0 | 0 | ++ | ++
Marchionni et al. | NR | NR | NR | NR | NR | ++
Group Cardiac Rehabilitation without exercise component
Stern et al. | NR | NR | NR | NR | ++ | NR
PRECOR -counseling arm | NR | 0 | NR | NR | NR | ++
Jones & West | NR | 0 | NR | 0 | 0 | 0
DIET | + | NR | NR | NR | NR | NR
Individual Counselling
Ornish et al. (83) | ++ | + | NR | NR | NR | ++
SCRIP | ++ | ++ | + | ++ | NR | NR
DeBusk et al. and Taylor et al. (1997) | ++ | ++ | NR | ++ | NR | ++
Fitzgerald et al. | NR | NR | NR | NR | NR | NR
Naylor et al. (94) | NR | NR | NR | NR | 0 | 0
Cupples & McKnight | + | + | + | ++ | NR | ++
M-HART | NR | NR | NR | NR | + | NR
huCarlsson et al. (1997) | NR | + | NR | NR | NR | NR
Carlsson (1998) | ++ | NR | NR | ++ | NR | NR
Campbell et al.
−12m f/u | ++ | 0 | ++ | ++ | ++ | ++
−56 m year f/u | + | 0 | + | 0 | 0 | 0
Jolly et al. | + | 0 | + | 0 | 0 | 0
Naylor & McCauley (99) | NR | NR | NR | NR | + | +
Allison et al. (99) | + | ++ | NR | ++ | NR | NR
Allison et al. (2000) | + | 0 | 0 | 0 | NR | NR
Moher et al | ++ | ++ | ++ | 0 | 0 | NR
Stagmo et al. | + | NR | NR | + | NR | NR
McHugh et al. | ++ | ++ | ++ | NR | ++ | ++
Higgins et al. | + | 0 | NR | NR | NR | ++
Allen et al. | ++ | NR | NR | + | NR | NR
COACH pilot | ++ | NR | NR | 0 | NR | NR
COACH | ++ | 0 | ++ | ++ | ++ | ++
ELMI | 0 | 0 | 0 | NR | 0 | 0
Young et al. | NR | NR | NR | NR | NR | NR
REACH | 0 | NR | NR | 0 | NR | NR

Use of proven efficacious therapies “encompasses both increased prescription rate by clinicians and/or increased compliance by patients.”

++ Statistically significant benefit seen in the intervention arm vs. control arm.

+ Trend towards better outcomes in the intervention arm, but didn’t reach statistical significance.

0 No appreciable difference between the intervention arm and control arm.

NR Not reported in study.

Other Endpoints: Eighteen of the 30 trials evaluating quality of life or functional status reported statistically significantly better scores in those patients exposed to the intervention programs, although the effect sizes were generally small (Table 3). Only 7 of these trials[30,44,49,50,65,66,105] described the costs of the intervention- while 2[30,50] reported that their intervention was cost-saving, only 1 performed formal cost-effectiveness analyses (and demonstrated an incremental cost per quality-adjusted life year of £1097). Another trial did not report costs, but did report that patients in the intervention arm had fewer visits to physicians as outpatients, fewer emergency room visits, less laboratory testing, and fewer total hospital days in follow-up than control patients.[83] Another trial reported statistically significantly lower inpatient bed days in intervention arm patients over 4 years of follow-up compared to controls (Dr. M. Vale, personal communication, January 10 2005).[81]

## Methodologic Quality

None of these trials were double-blind (not surprising considering the nature of the intervention) and very few described randomization procedures or accounted for discrepancies between recruitment and follow up sample sizes. As a result, Jadad quality scores were clustered around 2 (Table 4). None of the trials reported side effects with the secondary prevention programs beyond the adverse clinical outcomes described below.

Table 4 Methodologic Quality of Included Studies

Study | Described as Randomized | Method of Randomization Described and Appropriate | Description of Withdrawals or Losses to Follow-Up | Jadad Score | Allocation Concealment
Comprehensive Cardiac Rehabilitation
Sivarajan et al. | Yes | No | Yes | 2 | Unclear
Vermeulen et al. | Yes | No | Yes | 2 | Unclear
Bengtsson | Yes | No | Yes | 2 | Unclear
WHO trial | Yes | Yes | No | 2 | Unclear
Ornish et al. (90, 98) | Yes | No | Yes | 2 | Unclear
Oldridge et al. | Yes | No | No | 1 | Unclear
PRECOR., | Yes | No | Yes | 2 | Unclear
Fridlund et al. | Yes | No | Yes | 2 | Unclear
Engblom et al. | Yes | No | No | 1 | Unclear
Heidelberg Trial | Yes | No | Yes | 2 | Adequate
Bell | Yes | No | Yes | 2 | Unclear
Johnston et al. | Yes | No | Yes | 2 | Unclear
Lisspers et al. | Yes | No | Yes | 2 | Unclear
Toobert et al. | Yes | No | Yes | 2 | Unclear
Seki et al. | Yes | No | Yes | 2 | Adequate
Sundin et al. | Yes | No | No | 1 | Unclear
Yu et al | Yes | No | No | 1 | Unclear
Vestfold Heartcare | Yes | No | No | 1 | Adequate
Marchionni et al. | Yes | No | Yes | 2 | Unclear
Cardiac rehabilitation
Stern et al. | Yes | No | No | 1 | Unclear
PRECOR. | Yes | No | Yes | 2 | Unclear
Jones and West | Yes | No | Yes | 2 | Adequate
D.I.E.T. | Yes | No | No | 1 | Unclear
Individual counseling
Ornish et al. (83) | Yes | Yes | No | 2 | Unclear
SCRIP | Yes | Yes | Yes | 3 | Adequate
DeBusk et al.; Taylor et al. (97) | Yes | Yes | Yes | 3 | Adequate
Fitzgerald et al. | Yes | No | Yes | 2 | Unclear
Naylor et al. (94) | Yes | No | Yes | 2 | Unclear
Cupples and McKnight | Yes | Yes | Yes | 3 | Adequate
M-HART | Yes | No | Yes | 2 | Adequate
Carlsson et al. | Yes | No | Yes | 2 | Unclear
Campbell et al. | Yes | Yes | Yes | 3 | Adequate
Jolly et al. | Yes | No | Yes | 2 | Adequate
Naylor and McCauley (99) | Yes | Yes | Yes | 3 | Adequate
Allison et al. (99) | Yes | No | Yes | 2 | Unclear
Allison et al. (00) | Yes | Yes | No | 2 | Unclear
Moher et al. | Yes | Yes | Yes | 3 | Unclear
Stagmo et al. | Yes | No | Yes | 2 | Unclear
McHugh et al. | Yes | No | Yes | 2 | Unclear
Higgins et al. | Yes | No | Yes | 2 | Unclear
Allen et al. | Yes | Yes | Yes | 3 | Unclear
COACH pilot | Yes | No | Yes | 2 | Unclear
COACH | Yes | Yes | Yes | 3 | Unclear
ELMI | Yes | Yes | Yes | 3 | Unclear
Young et al. | Yes | Yes | Yes | 3 | Adequate
REACH | Yes | Yes | Yes | 3 | Unclear

* When there were several publications for the same study, quality assessment was done by using the primary publication.

COACH = Coaching patients On Achieving Cardiovascular Health Study; DIET = Dietary Intervention and Evaluation Trial; ELMI = Extensive Lifestyle Management Intervention ; ETICA = Exercise Training Intervention after Coronary Angioplasty; M-HART = Montreal Heart Attack Readjustment Trial; NEHDP = National Exercise and Heart Disease Project; REACH= Reinforcing Education About Cholesterol; SCRIP = Stanford Coronary Risk Intervention Project.

## Exploring the impact of program components

Program Descriptions (Table 5a,b,c and Appendix E): Physicians adopted a coordinating role in only 4 programs (9%); conversely, 8 programs (17%) had no physician involvement. In the majority of interventions (52%) physicians only supervised exercise stress tests or exercise sessions. Most programs (78%) utilized professionals who were either specialists in cardiac rehabilitation or in the cardiac area. Only 15% of these programs reported being based on one or more theory of behavioral change; these included social cognitive, learning, and motivational theories. Only one quarter of the interventions were based on stated guidelines. The relatively recent emergence of guidelines for cardiac prevention and rehabilitation may account for this small proportion.

Table 5 Program Descriptions

Table 5a Characteristics of Comprehensive Cardiac Rehabilitation Programs

Study | Location | Time to initiation (weeks) | Mean Length (weeks) | Total time (hours) | Individualization degree | Physician Involvement | Theo Basis | Nurs/Pharm Prescribing | Phone Support | Specialist Profs | Based on stated guidelines/protocol
Sivarajan et al. | Hosp | 0 | 13 | 14.5 | 3 | ETT | X | X | X | • | X
Vermeulen et al. | Hosp | 6 | 6 | --- | 2 | ETT | X | X | X | --- | X
Bengtsson | Hosp | 4 | 16 | --- | 2 | ETT | X | X | X | • | X
WHO | Hosp | 2 | 156 | --- | 4 | Follow up | X | X | X | • | X
Ornish et al. (1990, 1998) | Comb | 6 | 52 | 1040 | 3 | Coord | X | X | • | • | •
Oldridge et al. | Hosp | 6 | 8 | 12 | 2 | ETT | X | X | X | • | X
PRECOR | Hosp | 8 | 6 | 9 | 3 | Teaching | X | X | X | • | X
Fridlund et al. | Hosp | 0 | 26 | 52 | 3 | Teaching | X | X | X | • | X
Engblom et al. | Hosp | 0 | 52 | 59 | 2 | ETT | X | X | X | X | X
Heidelberg Trial | Hosp | --- | 312 | --- | 2 | ETT | X | X | X | X | ---
Bell | Hosp | 8 | --- | --- | 2 | ETT | X | X | X | X | X
Johnston et al. | Hosp | 1 | 8 | 9 | 3 | ETT | X | X | X | • | X
Lisspers et al. | Comb | 2 | 52 | 140 | 2 | ETT | • | X | • | • | X
Toobert et al. | Comb | 26 | 104 | 117 | 3 | Screening | X | X | X | • | X
Seki et al. | Hosp | 204 | 26 | 26 | 3 | Coord | X | X | X | • | X
Sundin et al. | Comb | --- | 52 | 51 | 2 | ETT | • | X | X | • | X
Yu et al. | Comb | 6 | 10 | 48 | 2 | NONE | X | X | X | X | X
Vestfold Heartcare Study | Comb | 6 | 104 | 50 | 2 | Coord | • | X | X | • | •
Marchionni et al. | Comb | 6 | 8 | 38 | 3 | NONE | X | X | X | • | •

Table 5b Characteristics of Group Cardiac Rehabilitation Without Exercise Component Programs

Study | Location | Time to initiation (weeks) | Mean Length (weeks) | Total time (hours) | Individualization degree | Physician Invovelment | Theo Basis | Nurs/Pharm Prescribing | Phone Support | Specialist Profs | Based on stated guidelines/protocol
Stern | Hosp | 52 | 12 | 13.5 | 2 | ETT | X | X | X | X | X
PRECOR | Hosp | 8 | 6 | 9 | 3 | Teaching | X | X | X | • | X
Jones and West | Hosp | 4 | 7 | 14 | 3 | NONE | X | X | X | • | X
DIET | Comb | --- | 52 | 18 | 2 | ETT | X | X | X | X | X

Table 5c Characteristics of Individual Counseling Programs

Study | Location | Time to Initiation (weeks) | Mean Length (weeks) | Total time (hours) | Individualization degree | Physician Involvement | Theo Basis | Nurs/Pharm Prescribing | Phone Support | Specialist Profs | Based on stated guidelines/protocol
Ornish (1983) | Residential | 6 | 3 | 37.5 | 3 | Coord | X | X | • | • | X
SCRIP | Hosp | 21 | 208 | 60 | 5 | ETT | X | X | • | • | •
DeBusk et al . | Hosp | 16 | 52 | 9 | 4 | NONE | • | • | • | • | X
Fitzgerald et al. | Hosp | 1 | 12 | 19 | 2 | Screening | X | X | • | • | X
Naylor et al. | Hosp | 0 | 2 | 4 | 4 | ETT | X | X | • | • | X
Cupples and McKnight | GP | 406 | 104 | 2 | 5 | NONE | X | X | X | X | X
M--- HART | Home | 1 | 52 | 12 | 4 | ETT | X | X | • | • | •
Carlsson et al. (1997) | Hosp | 4 | 11 | 24 | 4 | Follow up | X | X | X | • | X
Carlsson (1998) | Hosp | 4 | 52 | 26 | 3 | Follow up | X | X | X | • | X
Campbell et al. | GP | 312 | 52 | 4.1 | 3 | ETT | X | • | • | • | •
Jolly et al. | GP | 0 | 52 | --- | 3 | ETT | • | X | • | • | X
Naylor and McCauley | Comb | 0 | 4 | 4 | 3 | ETT | X | X | • | X | X
Allison (1999) | Hosp | 12 | 4 | 16 | 3 | Follow up | X | • | X | • | •
Allison (2000) | Hosp | 2 | 26 | 2 | 3 | ETT | X | • | X | • | X
Moher et al. | GP | --- | 78 | --- | 0 | NONE | X | • | --- | --- | ---
Stagmo et al. | Hosp | 6 | 52 | 5.75 | 3 | Follow up | X | X | X | • | •
McHugh et al. | Comb | --- | --- | --- | 5 | ETT | • | X | • | • | •
Higgins et al. | Home | 1 | 52 | 6 | 5 | ETT | • | X | • | • | X
Allen et al. | Home | 0 | 52 | 4.5 | 4 | Lipid mment | X | • | • | • | X
COACH PILOT | Home | 2 | 26 | 1.5 | 5 | ETT | X | X | • | • | 3
COACH | Hosp | 2 | 24 | 1.5 | 2 | ETT | X | X | • | • | X
ELMI | Hosp | 8 | 16 | 40 | 3 | NONE | X | X | • | • | •
Young | Home | 1 | 8 | 6 | 3 | NONE | X | X | X | • | X
REACH | Home | 0 | 52 | 0.5 | 3 | ETT | X | X | • | • | X

Around one third of interventions were standardized in terms of components and content. Hence, all patients received a virtually identical program. The greatest proportion of programs (43%) had the level of individualization that would be expected with usual care, i.e. with inclusion and intensity of a limited range of prescribed exercise regimes based on exercise stress test results or, with counseling interventions, programs involving direct interactions with health professionals but little formalized or detailed patient assessment. However, 23% reported individualizing the components patients received and/or the content of these components based on assessments substantially more involved than is typical for usual care. This heightened level of individualization reflected significant and formalized individual assessment of needs, goals and preferences, and alteration thereon of program components offered and/or the specific content of a component. Five programs individualized both the components offered to patients and the contents of interventions within each component. The vast majority of programs (87%) did not include pharmacist or nurse prescribing of medications. Only 39% of these interventions incorporated telephone support of patients.

Meta-Regression: None of the program components described in Table 5 demonstrated a significant effect on all-cause mortality or on recurrent myocardial infarctions. While the lack of a significant effect for particular program components may be seen as a disappointing result, the converse is important to emphasize: namely, shorter programs and programs delivered by non-specialists were just as effective as longer programs and programs delivered by specialists (Figures 11 and 12 respectively). For example, programs containing 10 hours or less of direct or telephone-based contact between patients and health professionals were effective at reducing all-cause mortality (RR 0.80, 95% CI 0.68 to 0.95, n=4307 in 9 trials) and were at least as effective as longer programs (Figure 11). Further, interventions that were based in non-hospital settings were effective in reducing all-cause mortality (RR 0.76 95% CI 0.63 to 0.92; n=2628 in 3 trials) and compared well with hospital-based programs (RR 0.90, 95% CI 0.79 to 1.03, n=9057 in 21 trials).

Figure 11 All-cause mortality stratified by length of program (expressed in hours)

Figure 11: All-cause mortality stratified by length of program (expressed in hours)

Figure 12 All-cause mortality stratified by degree of health care provider specialization

Figure 12: All-cause mortality stratified by degree of health care provider specialization

For hospitalizations, programs with increased degrees of individualization had greater impacts (p<0.001 in the meta-regression, RR 0.74, 95% CI 0.65 to 0.85, for those programs classified as having individualized components consistent with, or greater than, usual care), as did programs with nurse prescribing (p=0.007), although it should be noted in the latter case that there was only one study (of those reporting on all-cause hospitalizations) that had a prescribing nurse- see Figures 13 and 14.

Figure 13 All-cause hospitalizations stratified by degree of individualization

Figure 14 All-cause hospitalizations stratified by nurse prescribing