# REFERENCES

1 Fox CS, Evans JC, Larson MG, Kannel WB, Levy D. Temporal trends in coronary heart disease mortality and sudden cardiac death from 1950 to 1999. The Framingham Heart Study. Circulation. 2004;110:522-7. [pmid: 15262842].
2 American Heart Association. Heart Disease and Stroke Statistics — 2005 Update. Dallas, Tex. American Heart Association. 2004.
3 Yusuf S, Reddy S, Ounpuu S, Anand S. Global burden of cardiovascular diseases, part I: General considerations, the epidemiologic transition, risk factors, and impact of urbanization. Circulation. 2001;104:2746-53. [pmid: 11723030].
4 Yusuf S, Hawken S, Ounpuu S, Dans T, Avezum A, Lanas F, et al. Effect of potentially modifiable risk factors associated with myocardial infarction in 52 countries (the INTERHEART study): case-control study. Lancet. 2004;364:937-52. [pmid: 15364185].
5 Majumdar SR, Tsuyuki RT, McAlister FA. Controlling the ischemic heart disease epidemic: strategies for the 21^st^ century. Can J Public Health. 2001;92:9-11. [pmid: 11257999].
6 Yusuf S. Two decades of progress in preventing vascular disease. Lancet. 2002;360:2-3. [pmid: 12114031].
7 Majumdar SR, McAlister FA, Furberg CD. From publication to practice in chronic cardiovascular disease – The Long and Winding Road. J Am Coll Cardiol. 2004;43:1738-42. [pmid: 15145092].
8 EUROASPIRE I and II Group. Clinical reality of coronary prevention guidelines: a comparison of EUROASPIRE I and II in nine countries. Lancet. 2001;357:995-1001. [pmid: 11293642].
9 Stafford RS, Radley DC. The underutilization of cardiac medications of proven benefit, 1990 to 2002. J Am Coll Cardiol. 2003;41:56-61. [pmid: 12570945].
10 Witt BJ, Jacobsen SJ, Weston SA, Killian JM, Meverden RA, Allison TG, et al. Cardiac rehabilitation after myocardial infarction in the community. J Am Coll Cardiol. 2004;44:988-96. [pmid: 15337208].
11 McCormick D, Gurwitz JH, Lessard D, Yarzebski J, Gore JM, Goldberg RJ. Use of aspirin, beta-blockers, and lipid-lowering medications before recurrent acute myocardial infarction: missed opportunities for prevention?. Arch Intern Med. 1999;159:561-67. [pmid: 10090112].
12 Majumdar SR, Gurwitz JH, Soumerai SB. Undertreatment of hyperlipidemia in the secondary prevention of coronary artery disease. J Gen Intern Med. 1999;14:711-17. [pmid: 10632815].
13 Campbell NC, Thain J, Dean HG, et al. Secondary prevention in coronary heart disease: baseline survey of provision in general practice. BMJ. 1998;316:1430-4. [pmid: 9572757].
14 Brady AJB, Oliver MA, Pittard JB. Secondary prevention in 24 431 patients with coronary heart disease: survey in primary care. BMJ. 2001;322:1463. [pmid: 11408303].
15 Califf RM, DeLong ER, Ostbye T, et al. Underuse of aspirin in a referral population with documented coronary artery disease. Am J Cardiol. 2002;89:653-61. [pmid: 11897205].
16 World Health Organisation. Adherence to long-term therapies: evidence for action. Geneva. WHO. 2003.
17 Benner JS, Glynn RJ, Mogun H, et al. Long-term persistence in use of statin therapy in elderly patients. JAMA. 2002;288:455-61. [pmid: 12132975].
18 Balady GJ, Ades PA, Comoss P, Limacher M, Pina IL, Southard D, et al. Core components of cardiac rehabilitation/secondary prevention programs. Circulation. 2000;102:1069-1073. [pmid: 10961975].
19 O’Connor GT, Buring JE, Yusuf S, Goldhaber SZ, Olmstead EM, Paffenbarger RS, et al. An overview of randomized trials of rehabilitation with exercise after myocardial infarction. Circulation. 1989;80:234-44. [pmid: 2665973].
20 Oldridge NB, Guyatt GH, Fischer ME, Rimm AA. Cardiac rehabilitation after myocardial infarction. Combined experience of randomized clinical trials. JAMA. 1988;260:945-50. [pmid: 3398199].
21 Dinnes J, Kleijnen J, Leitner M, Thompson D. Cardiac rehabilitation. Qual Health Care. 1999;8:65-71. [pmid: 10557673].
22 Jolliffe JA, Rees K, Taylor RS, Thompson D, Oldridge N, Ebrahim S. Exercise-based rehabilitation for coronary heart disease. The Cochrane Database of Systematic Reviews. 2001;(1). Art. No.: CD001800. [doi: 10.1002/14651858.CD001800].
23 Taylor RS, Brown A, Ebrahim S, Jolliffe J, Noorani H, Rees K, et al. Exercise-based rehabilitation for patients with coronary heart disease: systematic review and meta-analysis of randomized controlled trials. Am J Med. 2004;116:682-92. [pmid: 15121495].
24 Shephard RJ, Balady GJ. Exercise as cardiovascular therapy. Circulation. 1999;99:963-72. [pmid: 10027821].
25 McAlister FA, Lawson FME, Teo KK, Armstrong PW. Randomised trials of secondary prevention programs in coronary heart disease: systematic review. BMJ. 2001;323:957-62. [pmid: 11679383].
26 Pawson R. Evidence-based policy: The promise of ‘realist synthesis’. Evaluation. 2002;8(3):340-358.
27 Phillips CO, Singa RM, Rubin HR, Jaarsma T. Complexity of program and clinical outcomes of heart failure disease management incorporating specialist nurse-led heart failure clinics: A meta-regression analysis. European Journal of Heart Failure. 7:333-341. [pmid: 15718173].
28 Campbell NC, Thain J, Deans HG, Ritchie LD, Rawles JG, Squair JL. Secondary prevention clinics for coronary heart disease: randomised trial of effect on health. BMJ. 1998;316:1434-7. [pmid: 9572758].
29 Campbell NC, Ritchie LD, Thain J, Deans HG, Rawles JG, Squair JL. Secondary prevention in coronary heart disease: a randomised trial of nurse led clinics in primary care. Heart. 1998;80:447-52. [pmid: 9930042].
30 Naylor MD, Brooten D, Campbell R, Jacobsen BS, Mezey MD, Pauly MV, et al. Comprehensive discharge planning and home follow-up of hospitalized elders. A randomized clinical trial. JAMA. 1999;281:613-20. [pmid: 10029122].
31 Naylor MD, McCauley KM. The effects of a discharge planning and home follow-up intervention on elders hospitalized with common medical and surgical cardiac conditions. J Cardiovasc Nurs. 1999;14:44-54. [pmid: 10533691].
32 World Health Organization Report 84: Rehabilitation and comprehensive secondary prevention after acute myocardial infarction. Copenhagen. 1983:1-99.
33 Kallio V, Hamalainen H, Hakkila J, Luurila OJ. Reduction in sudden deaths by a multifactorial intervention programme after acute myocardial infarction. Lancet. 1979;ii:1091-4. [pmid: 91836].
34 Hamalainen H, Luurila OJ, Kallio V, Knuts L-R, Arstila M, Hakkila J. Long-term reduction in sudden deaths after a multifactorial intervention programme in patients with myocardial infarction: 10-year results of a controlled investigation. Eur Heart J. 1989;10:55-62. [pmid: 2564823].
35 Hamalainen H, Luurila OJ, Kallio V, Knuts L-R. Reduction in sudden deaths and coronary mortality in myocardial infarction patients after rehabilitation. Eur Heart J. 1995;16:1839-44. [pmid: 8682016].
36 Taylor CB, Miller NH, Smith PM, DeBusk RF. The effect of a home-based, case-managed, multifactorial risk-reduction program on reducing psychological distress in patients with cardiovascular disease. Journal of Cardiopulmonary Rehabilitation. 1997;17:157-62. [pmid: 9187981].
37 Murchie P, Campbell NC, Ritchie LD, Simpson JA, Thain J. Secondary prevention clinics for coronary heart disease: four year follow up of a randomised controlled trial in primary care. BMJ. 2003;326:84. [pmid: 12521974].
38 Murchie P, Campbell NC, Ritchie LD, Deans HG, Thain J. Effects of secondary prevention clinics on health status in patients with coronary heart disease: 4 year follow-up of a randomized trial in primary care. Family Practice. 2004;21(5):567-74. [pmid: 15367480].
39 Niebauer J, Hambrecht R, Velich T, Hauer K, Marburger C, Kaulberer B, et al. Attenuated progression of coronary artery disease after 6 years of multifactorial risk intervention. Circulation. 1997;96:2534-41. [pmid: 9355890].
40 Cupples ME, McKnight A. Five year follow up of patients at high cardiovascular risk who took part in randomised controlled trial of health promotion. BMJ. 1999;319:687-8. [pmid: 10480826].
41 P.RE.COR. Group. Comparison of a rehabilitation programme, a counselling programme and usual care after an acute myocardial infarction: results of a long-term randomized trial. European Heart Journal. 1991;12:612-6. [pmid: 1874262].
42 Vermeulen A, Lie KI, Durrer D. Effects of cardiac rehabilitation after myocardial infarction: Changes in coronary risk factors and long-term prognosis. Am Heart J. 1983;105:798-801. [pmid: 6846123].
43 Haskell WL, Alderman EL, Fair JM, Maron DJ, Mackey SF, Superko R, et al. Effects of intensive multiple risk factor reduction on coronary atherosclerosis and clinical cardiac events in men and women with coronary artery disease. The Stanford Coronary Risk Intervention Project (SCRIP). Circulation. 1994;89:975-90. [pmid: 8124838].
44 DeBusk RF, Houston Miller N, Superko R, Dennis CA, Thomas RJ, Lew HT, et al. A case-management system for coronary risk factor modification after acute myocardial infarction. Ann Intern Med. 1994;120:721-9. [pmid: 8147544].
45 Cupples ME, McKnight A. Randomised controlled trial of health promotion in general practice for patient at high cardiovascular risk. BMJ. 1994;309:993-6. [pmid: 7950723].
46 Jones DA, West RR. Psychological rehabilitation after myocardial infarction: multicentre randomized controlled trial. BMJ. 1996;313:1517-21. [pmid: 8978226].
47 Frasure-Smith N, Lesperance F, Prince RH, Verrier P, Garber RA, Juneau M, et al. Randomised trial of home-based psychosocial nursing intervention for patients recovering from myocardial infarction. Lancet. 1997;350:473-9. [pmid: 9274583].
48 Jolly K, Bradley F, Sharp S, Smith H, Thompson S, Kinmonth AL, et al. for the SHIP Collaborative Group. Randomised controlled trial of follow up care in general practice of patients with myocardial infarction and angina: final results of the Southampton heart integrated care project (SHIP). BMJ. 1999;318:706-11. [pmid: 10074017].
49 Fitzgerald JR, Smith DM, Martin DK, Freedman JA, Katz BP. A case manager intervention to reduce readmissions. Arch Intern Med. 1994;154:1721-9. [pmid: 8042889].
50 Naylor M, Brooten D, Jones R, Lavizzo-Mourey R, Mezey M, Pauly M. Comprehensive discharge planning for the hospitalized elderly. Ann Intern Med. 1994;120:999-1006. [pmid: 8185149].
51 Allen JK, Blumenthal RS, Margolis S, Young DR, Miller ER III, Kelly K. Nurse case management of hypercholesterolemia in patients with coronary heart disease: results of a randomized clinical trial. American Heart Journal. 2002;144:678-86. [pmid: 12360165].
52 Allison TG, Farkouh ME, Smars PA, Evans RW, Squires RW, Gabriel SE, et al. Management of coronary risk factors by registered nurses versus usual care in patients with unstable angina pectoris (A chest pain evaluation in the emergency room (CHEER) substudy). American Journal of Cardiology. 2000;86:133-8. [pmid: 10913471].
53 Allison TG, Squires RW, Johnson BD, Gau GT. Achieving national cholesterol education program goals for low-density lipoprotein cholesterol in cardiac patients: importance of diet, exercise, weight control, and drug therapy. Mayo Clinic Proceedings. 1999;74:466-73. [pmid: 10319076].
54 Bengtsson K. Rehabilitation after myocardial infarction. A controlled study. Scandinavian Journal of Rehabilitation Medicine. 1983;15:1-9. [pmid: 6828827].
55 Carlsson R. Serum cholesterol, lifestyle, working capacity and quality of life in patients with coronary artery disease. Experiences from a hospital-based secondary prevention programme. Scandinavian Cardiovascular Journal Supplement. 1998;50:1-20. [pmid: 9802147].
56 Carlsson R, Lindberg G, Westin L, Israelsson B. Influence of coronary nursing management follow up on lifestyle after acute myocardial infarction. Heart. 1997;77:256-9. [pmid: 9093045].
57 Engblom E, Ronnemaa T, Hamalainen H, Kallio V, Vanttinen E, Knuts L-R. Coronary heart disease risk factors before and after bypass surgery: results of a controlled trial on multifactorial rehabilitation. European Heart Journal. 1992;13:232-7. [pmid: 1348226].
58 Engblom E, Korpilahti K, Hamaleinen H, Ronnemaa T, Puukka P. Quality of life and return to work 5 years after coronary artery bypass surgery. Long-term results of cardiac rehabilitation. J Cardiopulm Rehabil. 1997;17:29-36. [pmid: 9041068].
59 Fridlund B, Hogstedt B, Lidell E, Larsson PA. Recovery after myocardial infarction. Effects of a caring rehabilitation programme. Scandinavian Journal of Caring Science. 1991;5(1):23-32.
60 Higgins HC, Hayes RL, McKenna KT. Rehabilitation outcomes following percutaneous coronary interventions (PCI). Patient Education and Counseling. 2001;43:219-30. [pmid: 11384820].
61 Johnston M, Foulkes J, Johnston DW, Pollard B, Gudmundsdottir H. Impact on patients and partners of inpatient and extended cardiac counselling and rehabilitation: a controlled trial. Psychosomatic Medicine. 1999;61:225-33. [pmid: 10204976].
62 Lear SA, Ignaszewski A, Linden W, Brozic A, Kiess M, Spinelli JJ, et al. The extensive lifestyle management intervention (ELMI) following cardiac rehabilitation trial. European Heart Journal. 2003;24:1920-7. [pmid: 14585250].
63 Lichtman JH, Amatruda J, Yaari S, Cheng S, Smith GL, Mattera JA, et al. Clinical trial of an educational intervention to achieve recommended cholesterol levels in patients with coronary artery disease. American Heart Journal. 2004;147:522-8. [pmid: 14999204].
64 Lisspers J, Sundin O, Hofman-Bang C, Nordlander R, Nygren A, Ryden L, et al. Behavioral effects of a comprehensive, multifactorial program for lifestyle change after percutaneous transluminal coronary angioplasty: a prospective, randomized, controlled study. Journal of Psychosomatic Research. 1999;46(2):143-54. [pmid: 10098823].
65 Masley S, Phillips S, Copeland JR. Group office visits change dietary habits of patients with coronary artery disease. The dietary intervention and evaluation trial (D.I.E.T.). Journal of Family Practice. 2001;50(3):235-9. [pmid: 11252212].
66 Marchionni N, Fattirolli F, Fumagalli S, Oldridge N, Del Lungo F, Morosi L, et al. Improved exercise tolerance and quality of life with cardiac rehabilitation of older patients after myocardial infarction. Results of a randomized, controlled trial. Circulation. 2003;107:2201-6. [pmid: 12707240].
67 McHugh F, Lindsay GM, Hanlon P, Hutton I, Brown MR, Morrison C, et al. Nurse led shared care for patients on the waiting list for coronary artery bypass surgery: a randomised controlled trial. Heart. 2001;86:317-23. [pmid: 11514487].
68 Moher M, Yudkin P, Wright L, Turner R, Fuller A, Schofield T, et al. Cluster randomised controlled trial to compare three methods of promoting secondary prevention of coronary heart disease in primary care. BMJ. 2001;322:1-7. [pmid: 11141128].
69 Oldridge N, Guyatt G, Jones N, Crowe J, Singer J, Feeny D, McKelvie R, et al. Effects on quality of life with comprehensive rehabilitation after acute myocardial infarction. American Journal of Cardiology. 1991;67:1084-9. [pmid: 2024598].
70 Ornish D, Scherwitz LW, Doody RS, Kesten D, McLanahan SM, Brown SE, et al. Effects of stress management training and dietary changes in treating ischemic heart disease. JAMA. Jan 7. 1983;249(1):54-9. [pmid: 6336794].
71 Ornish D, Brown SE, Scherwitz LW, Billings JH, Armstrong WT, Ports TA, et al. Can lifestyle changes reverse coronary heart disease? The Lifestyle Heart Trial. Lancet. Jul 21. 1990;336(8708):129-33. [pmid: 1973470].
72 Ornish D, Scherwitz LW, Billings JH, Brown SE, Gould KL, Merritt TA, et al. Intensive lifestyle changes for reversal of coronary heart disease. JAMA. 1998;280(23):2001-7. [pmid: 9863851].
73 Schuler G, Hambrecht R, Schlierf G, Niebauer J, Hauer K, Neumann J, et al. Regular physical exercise and low-fat diet. Effects on progression of coronary artery disease. Circulation. 1992;86(1):1-11. [pmid: 1617762].
74 Seki E, Watanabe Y, Sunayama S, Iwama Y, Shimada K, Kawakami K, Sato M, Sato H, Mokuno H, Daida H. Effects of phase III cardiac rehabilitation programs on health-related quality of life in elderly patients with coronary artery disease: Juntendo Cardiac Rehabilitation Program (J-CARP). Circ J. 2003;67(1):73-7. [pmid: 12520156].
75 Sivarajan ES, Bruce RA, Lindskog BD, Almes MJ, Belanger L, Green B. Treadmill test responses to an early exercise program after myocardial infarction: a randomized study. Circulation. 1982;65(7):1420-8. [pmid: 7074797].
76 Stagmo M, Westin L, Carlsson R, Israelsson B. Long-term effects on cholesterol levels and the utilization of lipid-lowering drugs of a hospital-based programme for secondary prevention of coronary artery disease. Journal of Cardiovascular Risk. 2001;8:243-8. [pmid: 11551003].
77 Stern MJ, Gorman PA, Kaslow L. The group counselling v exercise therapy study. A controlled intervention with subjects following myocardial infarction. Archives of Internal Medicine. 1983;143:1719-25. [pmid: 6615094].
78 Sundin O, Lisspers J, Hofman-Bang C, Nygren A, Ryden L, Ohman A. Comparing multifactorial lifestyle interventions and stress management in coronary risk reduction. International Journal of Behavioral Medicine. 2003;10(3):191-204. [pmid: 14525716].
79 Toobert DJ, Glasgow RE, Radcliffe JL. Physiologic and related behavioral outcomes from the Women’s Lifestyle Heart Trial. Ann Behav Med. 2000;22(1):1-9. [pmid: 10892523].
80 Vale MJ, Jelinek MV, Best JD, Santamaria JD. Coaching patients with coronary heart disease to achieve the target cholesterol: a method to bridge the gap between evidence-based medicine and the “real world” – randomized controlled trial. Journal of Clinical Epidemiology. 2002;55:245-52. [pmid: 11864795].
81 Vale MJ, Jelinek MV, Best JD, Dart AM, Grigg LE, Hare DL, et al. Coaching patients on achieving cardiovascular health (COACH). Archives of Internal Medicine. 2003;163:2775-83. [pmid: 14662633].
82 The Vestfold Heartcare Study Group. Influence on lifestyle measures and five-year coronary risk by a comprehensive lifestyle intervention programme in patients with coronary heart disease. European Journal of Cardiovascular Prevention and Rehabilitation. 2003;10:429-37. [pmid: 14671465].
83 Young W, Rewa G, Goodman SG, Jaglal SB, Cash L, Lefkowitz C, et al. Evaluation of a community-based inner-city disease management program for postmyocardial infarction patients: a randomized controlled trial. CMAJ. 2003;169(9):905-10. [pmid: 14581307].
84 Yu C-M, Li LS-W, Ho HH, Lau C-P. Long-term changes in exercise capacity, quality of life, body anthropometry, and lipid profiles after a cardiac rehabilitation program in obese patients with coronary heart disease. American Journal of Cardiology. 2003;91(1):321-5. [pmid: 12565088].
85 Bell JM. A comparison of a multi-disciplinary home based cardiac rehabilitation programme with comprehensive conventional rehabilitation in post-myocardial infarction patients. PhD Thesis. London, United Kingdom. University of London. 1998.
86 Mant J, Hicks N. Detecting differences in quality of care: the sensitivity of measures of process and outcome in treating acute myocardial infarction. BMJ. 1995;311:793-6. [pmid: 7580444].
87 McAlister FA, Stewart S, Ferrua S, McMurray JJV. Multidisciplinary strategies for the management of heart failure patients at high risk for admission: A systematic review of randomized trials. J Am Coll Cardiol. 2004;44:810-9. [pmid: 15312864].
88 Koertge J, Weidner G, Elliott-Eller M, Scherwitz L, Merritt-Worden TA, Marlin R, et al. Improvement in medical risk factors and quality of life in women and men with coronary artery disease in the Multicentre Lifestyle Demonstration Project. Am J Cardiol. 2003;91:1316-22. [pmid: 12767423].
89 DeVries A, Palmer A, Scheib C, Day B, Bennett S, Fetterolf D, Kantz T. Highmark Blue Cross Blue Shield. Medical Management Analysis: Financial Impact of the Dr. Dean Ornish Program for Reversing Heart Disease. February. 14. 2002;4:3.
90 Beswick AD, Rees K, Griebsch I, Taylor FC, Burke M, West RR, Victory J, Brown J, Taylor RS, Ebrahim S. Provision, uptake and cost of cardiac rehabilitation programmes: improving services to under-represented groups. NHS HTA Report Project Code 99/21/02. 2004;8(41).
91 Hambrecht R, Wolff A, Gielen S, et al. Effect of exercise on coronary endothelial function in patients with coronary artery disease. N Engl J Med. 2000;342:454-60. [pmid: 10675425].
92 Clark AM, Hartling L, Vandermeer B, McAlister FA. Randomized trials of secondary prevention programs in coronary heart disease: a systematic review. Ann Intern Med. 2005;143:659-72. [pmid: 16263889].
93 Redelmeier DA, Tan SH, Booth GL. The treatment of unrelated disorders in patients with chronic medical diseases. N Engl J Med. 1998;338:1516-20. [pmid: 9593791].
94 Thomas RJ, Miller NH, Lamendola C, Berra K, Hedback B, Durstine JL, et al. National survey of gender differences in cardiac rehabilitation programs. Patient characteristics and enrollment patterns. Journal of Cardiopulmonary Rehabilitation. 1996;16(6):402-12. [pmid: 8985799].
95 Milani RV, Lavie CJ. Prevalence and effects of cardiac rehabilitation on depression in the elderly with coronary heart disease. American Journal of Cardiology. 1998;81(10):1233-6. [pmid: 9604957].
96 Majeed FA, Cook DG. Age and sex differences in the management of ishaemic heart disease. Public Health. 1996;110:7-12. [pmid: 8685314].
97 Lavie CJ, Milani RV. Cardiac rehabilitation and preventive cardiology in the elderly. Cardiology Clinics. 1999;17(1):233-42. [pmid: 10093776].
98 Ades PA, Waldmann ML, Gillespie C. A controlled trial of exercise training in older coronary patients. Journal of Gerontology. 1995;50A:M7-11.
99 Clark AM, Sharp C, MacIntyre PD. The role of age in moderating access to cardiac rehabilitation in Scotland. Ageing and Society. 2002;22:501-515.
100 Oldridge N. Cardiac rehabilitation in the elderly. Aging (Milano). 1998;10(4):273-83. [pmid: 9825018].
101 British Heart Foundation. Coronary Heart Disease Statistics. London. BHF. 2004.
102 Mosca L, Appel LJ, Benjamin EJ, Berra K, Chandra-Strobos N, Fabunmi RP, et al. Evidence-Based Guidelines for Cardiovascular Disease Prevention in Women. Circulation. 2004;109(5):672-693. [pmid: 14761900].
103 Cooper AF, Jackson G, Weinman J, Horne R. Factors associated with cardiac rehabilitation attendance: a systematic review of the literature. Clinical Rehabilitation. 2002;16:541-552. [pmid: 12194625].
104 Schulz KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias. JAMA. 1995;273:408-12. [pmid: 7823387].
105 Raftery JP, Yao GL, Murchie P, Campbell NC, Ritchie LD. Cost effectiveness of nurse led secondary prevention clinics for coronary heart disease in primary care: follow up of a randomized controlled trial. BMJ. 2005;330:707. [pmid: 15716289].