# METHODS

## Searching for relevant studies

We searched the following electronic databases to identify human randomized trials published in English: Medline 1966–2004; Cochrane Central Register of Controlled Trials, Issue 4, 2004; Embase 1980–2004; CINAHL 1982–2004; and, SIGLE 1980–2004. In order to identify recent publications, we also searched PubMed from January 2004 to December 2004 and conducted a cited reference search for our previous systematic review [25] in Web of Science (1999 to 2004). The searches (see Appendix A for listing of search strategy strings and results) were based on the following terms: case management, comprehensive health care, disease management, health services research, home care services, clinical protocols, patient care planning, quality of health care, rehabilitation, nurse led clinics, special clinics, and myocardial ischemia. To identify any studies missed by the literature searches, we hand-searched reference lists of all identified studies, as well as the reference list of a recent related review.[23] Finally, we screened references provided by the Centers for Medicare and Medicaid Services and content experts, including authors of the primary studies.

## Selection of studies and abstraction of data

For the systematic review, two of the investigators (AC and FM) independently reviewed the titles and abstracts of all citations to identify any studies reporting the impact of secondary prevention programs on death, MI, or hospitalization rates in patients with CAD (clinically manifest as angina, MI, or coronary revascularization). The full texts of all potentially relevant articles were obtained and reviewed by both investigators using pre-standardized data abstraction forms and a priori defined eligibility criteria. Any discrepancies were resolved by consensus.

All outcome data were extracted by AC and FM independently, and double-checked by BV. Outcomes were assigned according to the intention-to-treat principle and we accepted the definitions for each outcome used by the investigators in the primary studies. Original investigators were contacted to clarify the published data: 27 of the 31 study authors contacted provided further data.

Studies were excluded if they: were not randomized, were primary prevention studies (ie. restricted to patients without documented CAD), evaluated single-modality interventions (such as exercise-only programs, yoga interventions, or telephone follow-up), tested interventions delivered to hospitalized patients rather than outpatients, did not include a “usual care” arm, or tested interventions that were not provided by health professionals (such as letter reminders, self help groups, self-directed interventions, or general health promotion interventions). Studies in which patients with multiple diseases were enrolled were included if the outcomes for patients with coronary heart disease were reported separately or if that data was provided by the study principal investigator when contacted.

Two of the investigators (AC and FM) assigned each reported intervention independently to one of 3 a priori defined groups: (1) Comprehensive Cardiac Rehabilitation (programs which included exercise with group education and counseling sessions about coronary risk factor management), (2) Group Cardiac Rehabilitation without exercise component (programs which included group education and counseling sessions about coronary risk factor management, but no structured exercise component), or (3) Individual Counseling (programs, usually delivered by specially trained nurses, involving individual education and counseling sessions and individual follow-up, either in person or by telephone, to encourage coronary risk factor optimization). Patient education was a key component of all 3 types of interventions (see Tables 1 and 5 for a more detailed description of the program in each included trial). Data on the methodological quality of the trials were also independently extracted and verified.

## Statistical analyses

Analyses were performed using RevMan 4.2 (The Cochrane Collaboration 2004). Our primary outcome was all-cause mortality. Secondary outcomes that were meta-analyzed were recurrent myocardial infarctions and hospitalizations. We attempted to obtain data on all-cause hospitalizations wherever possible; however for some trials, even after contact with the primary study authors, we could only obtain data on cardiovascular hospitalizations. We defined “hospitalization rate” as the number of patients in each trial arm who were hospitalized at least once (thus, each patient could only contribute one event to these analyses).

As the outcomes were relatively common, risk ratios were calculated and the I^2^ statistic was used to assess for heterogeneity in each outcome of interest. Studies were combined using the DerSimonian and Laird random effects model. Analyses were conducted for each of the three types of programs: comprehensive cardiac rehabilitation, cardiac rehabilitation (without exercise component), and individual counseling. For the primary analysis, we used data from the longest follow-up period reported in each trial. We also conducted analyses using the various follow-up periods reported (6, 12, 24, 36, 48, 56, 60, and 72 months).

Due to a lack of consistency in how they were measured and/or reported (ie. different trials used different scales or measurements and while some trials reported mean/median results for continuous variables others transformed these same variables into binary variables for analyses and reporting), we described, but did not meta-analyze, the following outcomes: effects on major cardiovascular risk factors (cholesterol, smoking, blood pressure), use of proven efficacious therapies, patient quality of life, and patient functional status or symptom scores. These were evaluated and categorized as: statistically significant benefit seen in the intervention arm versus the control arm; trend towards better outcomes in the intervention arm which did not reach statistical significance; or, no appreciable difference between the intervention and control arms. In order to standardize the reporting of results for non-dichotomous outcomes (such as change in cholesterol or blood pressure levels, quality of life, or functional status scores), we calculated standardized effect sizes by dividing the absolute difference between intervention and control arms by the standard deviation in the control arms. By convention, effect sizes <0.20 are considered trivially small, 0.50 moderate, and >0.80 large.

## Exploring the impact of program components on clinical outcomes: A meta-regression

The effectiveness of an intervention is not just a consequence of a small number of macro characteristics, such as program type. Other program characteristics and the context in which the intervention is introduced are also likely to influence its provision and possibly its effectiveness [26].

A meta-regression was therefore undertaken to identify the association of several components of programs (see Tables 5a,b,c) with our main outcomes: all-cause mortality, recurrent myocardial infarctions, and all-cause hospitalizations.

To provide more details regarding program characteristics and given the paucity of details in published reports, in order to conduct the meta-regression we had to contact primary study authors for further data on program characteristics (see Appendix C for the standardized email survey items sent to the primary study authors, Figure 10 for outline of survey steps, and Appendix D for summary of missing data before/after the survey). All 46 trials were screened by 2 investigators independently to extract the characteristics outlined in Appendix C. Further details were required for 34 of the trials- we could not trace 3 of the primary study authors (even using Google searches). Overall response rate to the survey was 87% (27/31), resulting in 36 additional variables being identified.

Figure 10 Survey steps

47 trials screened yielding 554 additional program characteristics 57 missing fields across 34 trials remained 31 trials contained recent contact information Contacts 3 trials could not be traced to an author with recent contact information 34 surveys sent 27 trial authors replied to survey (response rate 87%) -19 after the first request -8 after a second request two weeks later -1 author of 2 trials replied by telephone 2 surveys were sent to incorrect individuals with identical names as trial authors 2 authors did not reply within 3 weeks 1

Since we had a larger number of studies than most meta-analyses, we decided to do a forward step-wise multiple meta-regression rather than the univariate meta-regression that one is often restricted to with smaller numbers of studies. The following covariates were considered in the regression: location of study intervention (i.e. hospital, community, etc.), time to commencement after index event, mean length of study, number of intervention sessions, degree of individualization, presence of prescribing nurse or pharmacist, type of physician involvement, supplementary telephone support, and theoretical basis for treatment (i.e. stage of change, cognitive, etc.). As there have been no previous meta-regressions of secondary prevention programs, these co-variates were selected based on: the factors identified as being potentially salient during the Medicare Coverage Advisory Committee Meeting, the terms used in the Medicare Coverage Advisory Committee evaluative questions, the common dimensions along which secondary preventions programs tend to differ, and what data on programs would realistically be available. Due to the expected large disparity in values for continuous variables, the variables time to commencement after index event and number of sessions were analyzed on the logarithmic scale.