# INTRODUCTION

Although cardiovascular death rates in North America have declined over the past two decades,[1] cardiovascular disease remains the most common cause of death (38% of all deaths in the United States in 2002), hospitalization, and physician office visits (over 80 million visits in 2002), and accounts for a large portion of total health care costs in the United States (estimated direct and indirect costs for 2005 are over $393 billion).[2] Using data from the National Health and Nutrition Examination Survey (NHANES 1999–2002), it is estimated that over 70 million Americans have one or more types of cardiovascular disease and over 13 million have known coronary artery disease (CAD), however, the proportion with undiagnosed disease is likely several fold higher.[2] Indeed, it is estimated that a United States citizen suffers a coronary event every 26 seconds, with 41% dying within a year.[2] Of course, CAD is not a North American phenomenon and atherosclerotic cardiovascular disease is the leading cause of death worldwide.[3] A case-control study in nearly 30,000 subjects from 52 countries confirmed that 9 known coronary risk factors (Box 1) account for over 90% of the population attributable risks for CAD in both men and women, in all age subgroups, and across all regions.[4]

Box 1 Modifiable coronary risk factors (adapted from reference 4)

Modifiable Risk Factor | Prevalence in cases with myocardial infarction | Population Attributable Risk (99% CI) | Odds Ratio (99% CI) adjusted for age, gender, and smoking
Smoking | 65% | 36% (34% to 39%) | 2.3 (2.1–2.4)
Dyslipidemia | 33% | 54% (50% to 59%) | 3.9 (3.4–4.4)
Diabetes Mellitus | 18% | 12% (11% to 14%) | 3.1 (2.8–3.4)
Hypertension | 39% | 23% (22% to 25%) | 2.5 (2.3–2.7)
Abdominal Obesity | 46% | 34% (30% to 37%) | 2.2 (2.1–2.5)
Psychosocial Factors | - | 29% (23% to 36%) | 2.5 (2.2–2.9)
Daily consumption of fruits and vegetables | 36% | 13% (10% to 17%) | 0.7 (0.6–0.8)
Regular physical activity | 14% | 26% (20% to 32%) | 0.7 (0.7–0.8)
Regular alcohol consumption | 24% | 14% (9% to 20%) | 0.8 (0.7–0.9)
All of the above combined | - | 90% (88% to 92%) | 129.2 (90.2–185.0)

In the INTERHEART Study, “dyslipidemia” was defined as ApoB/ApoA1 Ratio in top quintile vs. lowest quintile; “abdominal obesity” was defined as waist/hip ratio > 0.90 in men and >0.83 in women; “psychosocial factors” was defined as positive exposure to depression, perceived stress at work or home, moderate or severe financial stress, low locus of control, and/or major life events; “regular physical activity” was defined as moderate or strenuous exercise for at least 4 hours per week; “regular alcohol consumption” was defined as 3 or more times per week.

Control of the CAD epidemic will require a multifaceted strategy that targets the 9 modifiable risk factors identified in the INTERHEART study and includes both primary prevention strategies (some designed for the general population and some targeting only high risk populations) and secondary prevention strategies (targeted at those with established CAD).[5] Despite the abundant evidence base for CAD prevention,[6] health outcomes studies consistently demonstrate suboptimal control of cardiovascular risk factors due to gaps in the application of this evidence to clinical practice that contribute to sub-optimal patient outcomes.[7–15] Furthermore, even when some therapies proven to be efficacious in preventing morbidity and mortality in patients with coronary disease are prescribed, patient compliance may be poor (from 43% to 75% at one year).[16,17] Secondary prevention programs are increasingly advocated as a means to improve management and outcomes for patients with CAD.

## What are Secondary Prevention Programs?

In this report, we employ the American Heart Association and the American Association of Cardiovascular and Pulmonary Rehabilitation definition of a secondary prevention program as one that “incorporates a multifaceted and multidisciplinary approach to overall cardiovascular risk reduction in patients with established coronary artery disease”.[18] Secondary prevention programs may include a number of components to achieve the overall goal of assessing and modifying cardiovascular risk factors in at-risk patients. In order to examine the effects of different types of secondary prevention programs, we a priori defined the following program types: (1) Comprehensive Cardiac Rehabilitation (programs that include exercise with group education and counseling sessions about coronary risk factor management), (2) Group Cardiac Rehabilitation without exercise component (programs that include group education and counseling sessions about coronary risk factor management, but no structured exercise component), or (3) Individual Counseling (programs, usually delivered by specially trained nurses, involving individual education and counseling sessions and individual follow-up, either in person or by telephone, to encourage coronary risk factor optimization).

## Rationale for this Review

While numerous reviews have shown that cardiac rehabilitation programs improve outcomes in MI survivors,[19–23] these conclusions were based largely on trials which tested supervised exercise programs versus no exercise post-MI. As activity levels are inversely proportional to cardiovascular mortality and exercise training confers substantial physiologic and clinical benefits,[24] it is not surprising that trials of exercise programs found positive treatment effects. However, few of the trials included in these reviews evaluated secondary prevention programs that were not primarily exercise-based. To address this gap in the literature, we performed a systematic review- in the 12 trials we identified (with 9803 patients), we found that multidisciplinary non-exercise based programs improved processes of care (namely prescription of proven efficacious secondary prevention therapies) and risk factor profiles, and reduced hospitalizations by 16% (95% confidence interval [CI] 6% to 24%), but did not have an appreciable impact on rates of death (RR 0.91, 95% CI 0.79–1.04) or recurrent myocardial infarction (RR 0.94, 95% CI 0.80–1.10).[25]

As current guidelines recommend that secondary prevention programs should not be restricted to supervised exercise programs but should rather address the full range of modifiable risk factors,[18] we conducted the current systematic review to expand our earlier work and to determine whether comprehensive secondary prevention programs (in contradistinction to exercise-only or similar single modality programs) prevent coronary events and/or death in patients with CAD.

Systematic reviews incorporating meta-analyses can determine the effectiveness of interventions. However, in pooling different studies the particular characteristics of different interventions tend to be “lost in the mix”[26] and meta-analyses cannot explain why some interventions are more effective than others.[27] To gain a comprehensive overview of the literature on secondary prevention programs, we therefore derived a survey to collect a wide range of additional quantitative and qualitative data on program characteristics from primary study authors. Finally, to identify to what degree program characteristics affect outcomes, we performed a meta-regression to examine the association of a priori defined co-variates with our main outcomes.