# DISCUSSION

In summary, the weight of the published randomized trial evidence suggests that comprehensive secondary prevention programs positively impact on processes of care (risk factor profiles, use of proven efficacious therapies) which are closely linked to subsequent morbidity and mortality in patients with CAD.[86] Pooling the data from those trials which reported subsequent rates of MI reveals a statistically significant 17% relative risk reduction in recurrent MIs over a median follow-up of 12 months. The majority of these programs also demonstrate improved symptom scores, exercise tolerance, or quality of life in participants. The mortality benefit derived from participation in the secondary prevention programs we identified became apparent with longer follow-up (47% at 2 years and 24% at 5 years). This is not surprising given that the natural history of atherosclerotic CAD dictates that changes in coronary risk factors would not be expected to produce immediate improvements in atherosclerotic plaque stability or coronary artery diameter. There was a statistically significant 15% relative risk reduction in hospitalizations (driven by a statistically significant 24% reduction in cardiovascular hospitalizations) over a median follow-up of 12 months. These early beneficial effects on hospitalizations mirror the findings of a recent systematic review of multidisciplinary strategies for patients with heart failure which found that such interventions reduce hospitalizations by 25% within 6 months of implementation.[87]

Some comprehensive lifestyle modification programs under consideration by the Medicare Coverage Advisory Committee were not included in our analysis as they had not been evaluated in randomized controlled trials. However, our analyses extend the evidence base from these other programs to show significant benefits on hard clinical endpoints. Though none of the papers included were replication studies (i.e. tested interventions found to be effective previously in different settings), subsequent studies have confirmed that the Ornish multi-component cardiac rehabilitation program [71] can be successfully taught and implemented at various sites in the United States [88] and should be cost-saving.[89] However, while this economic analysis suggests that cost reductions in the order of 30% to 60% for care within the first year are possible, the analyses are based on observational data (two concurrent cohorts followed for one year in one study, matched claims data analyses in another study, and two studies comparing actual costs after participation in the Ornish Program versus predicted costs) rather than randomized trial evidence.[89] A recent analysis of direct health care costs at 30 cardiac rehabilitation centres in the United Kingdom’s NHS for the fiscal year 2000–2001 reported an average cost of £486 per patient who completed a cardiac rehabilitation program (with most of the cost, or £354 per patient, being attributed to staff salary costs).[90] However, citing an average cost is misleading since program costs varied widely across centres (depending on duration of interventions and staff to patient ratios amongst other factors) and the investigators demonstrated that economies of scale could be achieved in that costs were projected to fall by 0.25% per patient for every 1% increase in patient throughput. Although very few of the trials we identified for this review reported costs, the reality is that the 1–2 year follow up period of many of these trials is too short anyway to fully evaluate the cost-effectiveness of secondary prevention programs and while studies with 5 and 10 year time horizons are ongoing, more studies that include long term measurement of outcomes and costs are needed.

Previously published systematic reviews of cardiac rehabilitation in survivors of myocardial infarction have reported survival benefits in the order of 20–24%. However, most of the trials included in those overviews evaluated single modality exercise-based interventions and thus were not included in our overview. For example, a recently published meta-analysis reported a statistically significant 20% reduction in all-cause mortality in 8432 patients; however, closer inspection of this report reveals that 40% of the data in the mortality analysis came from 13 trials that evaluated exercise-only programs and from 2 trials which were excluded from our systematic review because of lack of a usual care control arm.[23] Activity levels are inversely proportional to cardiovascular mortality and exercise training confers substantial physiologic and clinical benefits (including changes in endothelial function, autonomic tone, inflammatory markers)[24,91]. It is thus not surprising that trials comparing exercise training to no exercise found greater treatment effects than the trials included in our review which evaluated secondary prevention programs that were not primarily exercise-based. However, the selection of programs included in our review was driven by current guideline recommendations and the request of the Medicare Coverage Advisory Committee that secondary prevention programs should not include comparisons of supervised exercise programs versus no exercise (a control arm that is no longer “usual care”).[18,26] Our systematic review demonstrates that a wide variety of secondary prevention programs delivered by health care providers, in addition to having beneficial effects on patient risk factor profiles and quality of life/functional status, provide tangible reductions in clinically relevant endpoints such as hospitalization and death.

As a corollary to this review and in recognition of the interest of some in defining the impact of exercise-only programs, we conducted a systematic review of 17 trials (2566 patients) comparing supervised exercise training programs with no exercise and incorporated this data into a meta-comparison of exercise-based rehabilitation programs versus programs which did not incorporate an exercise training component.[92] While we demonstrated that supervised exercise training reduced mortality by 28% (95% CI 5% to 46%) compared to controls who did not receive exercise training, this degree of benefit was not statistically significantly different from the benefits seen with secondary prevention programs that did not incorporate a structured exercise component (mortality reduction 13%, 95% CI 1% to 24%).

Why didn’t the trials reporting 12 month outcome data (including over 9000 subjects) demonstrate a statistically significant survival benefit? First, 12 months was clearly too short to show a marked impact on mortality- this conclusion is not only supported by knowledge of the pathophysiology of atherosclerotic CAD but also by data demonstrating a significant survival benefit in those studies reporting outcomes over 2 years or more. It should be emphasized that studies which did evaluate coronary angiographic lesions at baseline and after 12 months did report statistically significant regression rates in patients compliant with comprehensive lifestyle modifications within 12 months even without significant changes in metabolic profiles or medication usage.[39,71] Second, the patients included in these studies were at sufficiently low risk over the first year after enrollment that the likelihood of detecting a beneficial effect was remote- indeed, the control event rates in these trials were substantially lower than those in other trials enrolling patients with clinically overt CAD. Third, the incremental benefit of secondary prevention programs over usual care may be very small in the settings in which the trials were carried out (where management in the “usual care” arm may be atypically close to optimal already). Indeed, secondary prevention programs are likely to be most beneficial in those settings where usual care is sub-optimal. Finally, it is possible that the labeling of patients with one disease for special attention in a disease-specific management program may have led to sub-optimal care for their co-morbid conditions and, as a result, no real difference in all-cause mortality.[93]

The overall effectiveness of secondary prevention programs should also be interpreted in the context of the unexplained inconsistencies in effectiveness between different types of programs. We attempted to ‘open the black box’ to identify what the key characteristics of successful programs were, which components were most influential, or how particular program or setting characteristics influenced patients and health outcomes. However, although we obtained detailed data from the vast majority of primary study authors, our meta-regression did not find any factors which significantly drove the results for all-cause mortality or recurrent MIs. The particular mechanisms of effect of interventions remain poorly understood. Translation of the theoretical benefits of secondary prevention programs into real-world patient benefit is also dependent on suitable patients being referred to, accessing, and completing the programs. Health outcomes research has consistently demonstrated that even in publicly funded health care systems where access is free, only a minority of patients (less than one quarter to one half) ultimately access these programs.[10,90,94] Moreover, those groups that are less likely to be referred, to attend, and to complete programs are often those in greatest need of additional support and risk reduction, such as women, the elderly, low income groups, and ethnic minorities.[90] These groups were underrepresented in the studies reviewed.

## Generalizability of the trial data

The trials included in this review enrolled relatively young patients- some even excluded patients over the age of 65 (see Tables 1 and 6). This raises potential concerns about the generalizability of our findings to this increasingly large segment of the population that is especially vulnerable to CAD. However, there is evidence that elderly patients derive similar benefits from secondary prevention programs as younger patients.[95–98] While it is now less common for programs to have age-based restrictions for entry, older adults are frequently excluded from programs due to a lack of program capacity to address their complex health needs or limited resources.[99,100] The effectiveness of programs for older patients may therefore be dependent not only on program content but also on program capacity to provide effective care to patients who have multiple co-morbidities.

Table 6 Number of trials with age-based exclusion criteria

Upper age limit (years) | Number of studies
>79 | 2
75–79 | 8
70–74 | 6
65–69 | 8
60–64 | 0
55–59 | 1
No upper age-based criteria used | 21

Women were also underrepresented in the studies reviewed (Table 7) and data were not available to examine results by gender. This imbalance is significant because although CAD remains the leading cause of death for women in most of the developed world [101], it is often erroneously viewed as principally being a “disease of men”. Gender differences in the investigation and management of CAD have been evident for many years.[102] Consequently, the need for improved and more responsive management of CAD in women has now been recognized by international guidelines.[102] While there is no evidence of any gender-based barriers to program benefit, women are consistently identified as being less likely to access programs.[94,103] To increase the strength of evidence supporting the benefits of programs to women, more women should be included in studies, and studies should examine the effectiveness of programs in males versus females.

Table 7 Proportion of women in trials

Proportion of women | Number of studies
0 % | 8
1%–10% | 2
11%–20% | 11
21–30% | 13
31–40% | 6
41–50% | 3
51–60% | 1
>61% | 2

Finally, as with any intervention that is efficacious in trial settings, the applicability of this evidence to the “real-world setting”, where compliance is likely to be highly variable and generally lower than that observed in trial participants, is a potential concern. This may lead some to conclude that the results we report should be viewed as a “best case scenario” for the impact of secondary prevention programs. However, this view neglects the fact that randomized trial participants assigned to the control arm often also receive care which is better than typical usual care. Indeed, as we pointed out earlier, the incremental benefit of secondary prevention programs over usual care may be very small in the settings in which these trials were carried out, where management in the “usual care” arm was often close to optimal already. Indeed, it is likely that secondary prevention programs will be more beneficial in other settings that are more akin to the “real world” of current clinical practice where usual care is suboptimal.

## Limitations of this Review

As with all systematic reviews, this study has a number of potential limitations. The most obvious arise from the primary data (lack of blinding in outcome ascertainment, lack of detail on whether randomization was conducted properly or whether allocation concealment was achieved, and our inability to identify unpublished studies- although we did not find any evidence for publication bias) and, as all tend to result in over-estimation of any treatment effects,[104] these factors should be taken into account when interpreting our summary estimates. Our interpretation of these trials and the generalizability of the programs are hampered by our inability, even with additional unpublished data from 87% of the trials and the use of meta-regression, to determine the incremental benefits of the various components of each intervention. Determining the optimal mix of interventions, including their frequency and duration, should be a priority for future research studies in this field. While some may criticize our choice of primary endpoints as being too broad to detect differences in “cardiac” morbidity and mortality, we believe that it is most appropriate to look at all-cause mortality or hospitalization as interventions to reduce resource use in one area can have unanticipated effects in another. Finally, we are unable to make a definitive comment on the cost-effectiveness and economic impact of the programs tested in these trials due to the paucity of relevant data and the likelihood that costs for program delivery will vary widely between different areas and different types of programs (depending on duration of the programs and staff-patient ratios in particular).