# CONCLUSION

In summary, although there was substantial variability in the interventions offered and the studies enrolled highly selected populations, secondary prevention programs do improve processes of care, coronary risk factor profiles, and functional status/quality of life. Though the optimal mix of interventions, including their frequency and duration, are unclear, these programs do reduce hospitalizations, subsequent myocardial infarctions, and mortality in patients with known CAD. While these programs appear to reduce health care resource use, their cost-effectiveness has been inadequately evaluated thus far in the literature. Thus, we believe that any policy decisions to implement secondary prevention programs on a wide scale should be accompanied by plans to rigorously evaluate long-term clinical and economic outcomes in participants and non-participants.