# Results of descriptive survey

Physician Involvement | Number of Studies (%)
None | 8 (17%)
ETT/Exercise Supervision | 24 (52%)
Follow up | 5 (11%)
Coordination | 4 (9%)
Lipid Management | 1 (2%)
Screening for Inclusion | 2 (4%)
Teaching | 2 (4%)

Theoretical Basis | Number of Studies n=46 (%)
None | 39 (85%)
Social Cognitive/Learning | 2 (4%)
Cognitive Behavioral/Motivation | 3 (7%)
Behavioral | 2 (4%)

Individualization | Number of Studies n=46 (%)
Unclear | 1 (2%)
Standardized components and contents | 14 (30%)
Individualized as per usual care | 20 (43%)
Individualized components or individualized contents | 6 (13%)
Individualized components and individualized contents | 5 (10%)

Nurse Prescribing | Number of Studies n=46 (%)
No | 40 (87%)
Yes | 6 (13%)

Phone Support | Number of Studies n=46 (%)
0. Unclear | 1 (2%)
1. No | 27 (59%)
2. Yes | 18 (39%)

Specialist CR/Cardiac Professionals | Number of Studies n=46 (%)
Unclear | 2 (4%)
No | 7 (17%)
Yes | 37 (79%)

Based on Stated Guidelines | Number of Studies n=46 (%)
Unclear | 2 (4%)
No | 34 (72%)
Yes | 10 (23%)