# Missing fields prior to and after author survey

Unclear variables | Prior to survey | After survey
Location of program | 3 | 3
Commencement | 10 | 3
Program length | 5 | 1
Session total | 17 | 8
Physician Involvement | 6 | 0
Theoretical Basis | 2 | 0
Individualization | 2 | 1
Nurse/Pharm Prescribing | 2 | 0
Telephone Support | 1 | 1
Specialist input | 7 | 2
Guidelines | 2 | 2
Total missing fields | 57 | 21