# List of Excluded Studies and Reasons for Exclusion (full references at end of table)

Author year | Source | Reason for exclusion
Ades and Coello 2000 | Database (WOS) | Guideline/review article
Akosah, Schaper, Havlik et al 2002 | Database | Not randomized
Aldana, Whitmer, Greenlaw et al 2003 | CMS | Not randomized
Ammerman, Keyserling, Atwood et al 2003 | Database (Medline) | Primary prevention
Angerer, Siebert, Kothny et al 2000 | CMS | Not randomized
Anonymous 1982 | Database | Primary prevention
Ariyo, Haan, Tangen et al 2000 | CMS | Not randomized
Arthur, Daniels, McKelvie 2000 | Database (Medline) | Did not report primary outcomes
Barnard, Massey, Cherny et al 1983 | CMS | Evaluated interventions which were not comprehensive disease management systems
Barnes, Trieber, Turner et al 1999 | CMS | Population not CHD
Bartels, Gerdes, Babin-Ebell et al 2002 | CMS | Guideline/review article
Beckie 1989 | Database | Did not report primary outcomes
Bennett, Blackall, Clapham et al 1989 | Database | Not randomized
Bentsson 1983 | Database | Methodological flaw (patients excluded after randomization)
Berglund, Nilsson, Ericksson et al 2000 | Database | Primary prevention
Berkman, Blumenthal, Burg et al 2003 | Database (Medline) | Evaluated interventions which were not comprehensive disease management systems
Bethell and Mullee 1990 | Reference list | Evaluated interventions which were not comprehensive disease management systems
Billings, Scherwitz, Sullivan et al 1996 | CMS | Guideline/review article
Bjarnason-Wehrens, Benesch, Bischoff et al 2003 | Database (WOS) | Non-English
Blair, Bryant, Bocuzzi 1988 | Database | Not randomized
Blumenthal, Jiang, Babyak et al 1997 | CMS | Not randomized
Bogden, Koontz, Williamson et al 1997 | Database | Did not report primary outcomes
Boulay and Prud’homme 2004 | Database (WOS) | Not randomized
Bramlet, King, Young et al 1997 | Database | Not randomized
Brown, Zhao, Chait et al 2001 | CMS | Drug interventions
Burell 1996 | CMS | Guideline/review article
Cambien, Richard, Ducimetiere et al 1981 | Database | Primary prevention
Campbell, Ritchie, Thain et al 1998 | Database (Embase) | Protocol only
Cannon, Braunwald, McCabe et al 2004 | CMS | Evaluated interventions which were not comprehensive disease management systems
Caracciolo, Davis, Sopko et al 1995 | CMS | Not randomized
Carlson, Johnson, Franklin et al 2000 | Database (WOS) | No usual care arm
Carney, Blumenthal, Stein et al 2001 | CMS | Not randomized
Castillo-Richmond, Schneider, Alexander et al 2000 | CMS | Evaluated interventions which were not comprehensive disease management systems
Chinaglia, Gaschino, Asteggiano et al 2002 | Database | Not randomized
Clark, Bakhai, Lacey et al 2004 | CMS | Not randomized
Coleman, Grothaus, Sandhu et al 1999 | Database | Did not report the outcomes for patients with CHD separately
Corti, Fuster, Fayad et al 2002 | CMS | Drug interventions
Coull, Taylor, Elton et al 2004 | Database (Medline) | Evaluated interventions which were not comprehensive disease management systems
Council on Clinical Cardiology and Council on Nutrition, Physical Activity and Metabolism 2003 | CMS | Guideline/review article
Cummings, Hughes, Weaver et al 1990 | Database | Did not report the outcomes for patients with CHD separately
Cundiff 2002 | CMS | Guideline/review article
DeBusk, Haskell, Miller et al 1985 | Database | Evaluated interventions which were not comprehensive disease management systems
DeBusk, Miller, Parker et al 2004 | Database (WOS) | Population not CHD
De Lorgeril, Salen, Martin et al 1999 | CMS | Evaluated interventions which were not comprehensive disease management systems
Denollet and Brutsaert 2001 | CMS | Not randomized
Detry, Vierendel, Vanbutsele et al 2001 | Database (WOS) | Not randomized
DeVries, Palmer, Scheib et al 2002 | CMS | Not randomized
DeVries, Day, Scott 2003 | CMS | Not randomized
Diehl 1998 | CMS | Not randomized
Dugan, Cohen 1998 | CMS | Guideline/review article
Dugmore, Tipson, Phillips et al 1999 | Database (Medline) | Evaluated interventions which were not comprehensive disease management systems
Eaker, Sullivan, Kelly-Hayes et al 2004 | CMS | Not randomized
Eddy 2000 | CMS | Guideline/review article
Ellingsen, Hjermann, Abdelnoor et al 2003 | Database (Medline) | Primary prevention
Elliott-Eller, Weidner, Pischke 2003 | CMS | Abstract
Engblom, Korpilahti, Hamalainen et al 1997 | Database | Did not report primary outcomes
Esposito, Giugliano, Nappo et al 2004 | CMS | Drug interventions
Esselstyn 1999 | CMS | Guideline/review article
Family Heart Study Group 1994 | Database | Primary prevention
Fields, Walton, Schneider et al 2002 | CMS | Protocol only
Flanagan, Cox, Paine et al 1999 | Database | Not randomized
Frasure-Smith and Prince 1985 | Database | Not randomized
Frasure-Smith, Lesperance, Gravel et al 2000 | CMS | Not randomized
Friedman, Thoreson, Gill et al 1984 | Database | Not randomized
Galatius, Gustafsson, Kistorp et al 2003 | Database | Not randomized
Geil, Anderson, Gustafson 1995 | CMS | Evaluated interventions which were not comprehensive disease management systems
George and Goldberg 2001 | CMS | Guideline/review article
Ghoncheh and Smith 2004 | CMS | Population not CHD
Gielen, Schuler, Hambrecht 2001 | CMS | Guideline/review article
Gleason, Bourdet, Koehn et al 2002 | CMS | Not randomized
Gould, Ornish, Scherwitz et al 1995 | CMS | Duplicate publication (same study population and follow-up period as Ornish 1998)
Gould, Ornish, Kirkeeide et al 1992 | CMS | Protocol only
Grimm for the MRFIT 1983 | Database | Primary prevention
Grundy, Cleeman, Merz et al 2004 | CMS | Guideline/review article
Gulati, Pandey, Arnsdorf et al 2003 | CMS | Not randomized
Hakim, Curb, Petrovitch et al 1999 | CMS | Evaluated interventions which were not comprehensive disease management systems
Hambrecht, Walther, Mobius-Winkler 2004 | CMS | Evaluated interventions which were not comprehensive disease management systems
Harris, Record, Gipson et al 1998 | Database | Not randomized
Hedback and Perk 1987 | Database | Not randomized
Imperial Cancer Research Fund | Database | Primary prevention
OXCHECK Study Group 1995 Jain, Uppal, Bhatnagar et al 1993 | CMS | Evaluated interventions which were not comprehensive disease management systems
Jukema, Bruschke, van Boven et al 1995 | CMS | Drug interventions
Kawachi, Sparrow, Vokonas et al 1994 | CMS | Not randomized
Ketola, Makela, Klockars 2001 | Database (WOS) | Primary prevention
Koertge, Weidner, Billings et al 2002 | CMS | Abstract
Koertge, Weidner, Elliott-Eller et al 2003 | CMS | Not randomized
Kornitzer, De Backer, Dramaix et al 1980 | Database | Primary prevention
Krachler 1997 | Reference list | Did not report primary outcomes
Kris-Etherton, Harris, Appel et al 2002 | CMS | Guideline/review article
Lampert, Joska, Burg et al 2002 | CMS | Not randomized
Lear, Ignaszewski, Linden et al 2002 | Database (WOS) | Protocol only
Lesperance, Frasure-Smith, Talajic et al 2002 | CMS | Not randomized
Lewin, Furze, Robinson et al 2002 | Database (Medline) | No usual care arm
Lewis and Resnik 1967 | Database | Did not report the outcomes for patients with CHD separately
Liao, Ma, Dong et al 2003 | Database (Embase) | Non-English
Lichtenstein and Van Horn 1998 | CMS | Guideline/review article
Lindholm, Ekbom, Dash et al 1995 | Database | Primary prevention
Maggioni 2000 | Database (Embase) | Guideline/review article
Malach and Imperato 2004 | CMS | Not randomized
Marra, Paolillo, Spadaccini et al 1985 | Database | Evaluated interventions which were not comprehensive disease management systems
Marshall, Penckofer, Llewellyn 1986 | Database | Not randomized
Matthews, Gump, Harris et al 2004 | CMS | Not randomized
Meer 1999 | Database (SIGLE) | Not randomized
Meland, Laerum, Ulvik 1997 | Database | Primary prevention
Merritt, Scherwitz, Brown et al 1990 | CMS | Abstract
Merritt, Ornish, Scherwitz et al 1995a | CMS | Abstract
Merritt, Ornish, Scherwitz et al 1995b | CMS | Abstract
Merritt-Worden, Pettengill, Ornish 2003 | CMS | Abstract
Miettinen, Pyorala, Olsson et al 1997 | CMS | Drug interventions
Miller, Erlinger, Young et al 2002 | CMS | Non-CHD population
Mittleman, Maclure, Sherwood et al 1995 | CMS | Not randomized
National Cholesterol Education Program, National Institutes of Health 2002 | CMS | Guidelines/review article
Ness, Hughes, Elwood et al 2002 | Database (Medline) | Evaluated interventions which were not comprehensive disease management systems
Nicholson, Sklar, Barnard et al 1999 | CMS | Evaluated interventions which were not comprehensive disease management systems
Oldenburg, Martin, Greenwood 1995 | Database | Did not report primary outcomes
Ornish 1998 | CMS | Not randomized
Ornish 2002 | CMS | Guideline/review article
Ornish and Pettengill 2003 | CMS | Abstract
Ornish 2004 | CMS | Guideline/review article
Ornish (chapter 8) | CMS | Guideline/review article
Ornish and Hart (chapter 34) | CMS | Guideline/review article
Pater, Ditlef Jacobsen, Rollag et al 2000 | Database (Embase) | Protocol only (no data presented)
Peiss, Kurleto, Rubenfire 1995 | Database | Not randomized
Pettengill, Pearson, Pifalo et al 2002 | CMS | Abstract
Pfisterer, Buser, Osswald et al 2003 | CMS | Not randomized
Picard, Schwartz, Ahn et al 1989 | Database | Evaluated interventions which were not comprehensive disease management systems
Pischke, Weidner, Billings J et al 2002 | CMS | Abstract
Pitt, Waters, Brown et al 1999 | CMS | Drug interventions
Pollock, Franklin, Balady et al 2000 | CMS | Guideline/review article
Pozen, Stechmiller, Harris et al 1977 | Database | Inpatient-based intervention
Prochaska, Johnson, Lee | CMS | Guideline/review article
Pyke, Wood, Kinmonth et al 1997 | Database | Primary prevention
Rahe, Ward, Hayes 1979 | Database | Did not report primary outcomes
Rihal, Raco, Gersh et al 2003 | CMS | Guideline/review article
Roderick, Ruddock, Hunt et al 1997 | Database | Primary prevention
Roman, Gutierrez, Luksic et al 1983 | Database | Evaluated interventions which were not comprehensive disease management systems
Rose, Heller, Pedoe et al 1980 | Database | Primary prevention
Rubenstein, Kahn, Reinisch et al 1990 | Database | Not randomized
Ruo, Rumsfeld, Hlatky et al 2003 | CMS | Not randomized
Scandinavian Simvastatin Survival Study 1994 | CMS | Drug interventions
Schectman, Wolff, Byrd et al 1996 | Database | Did not report the outcomes for patients with CHD separately
Schneider, Staggers, Alexander et al 1995 | CMS | Evaluated interventions which were not comprehensive disease management systems
Sdringola, Nakagawa, Nakagawa et al 2003 | CMS | Not randomized
Shaffer and Wexler 1995 | Database | Not randomized
Shintani, Beckham, Brown et al 2001 | CMS | Population not CHD
Simpson, Dixon, Bolli 2004 | Database (WOS) | Not randomized
Sivarajan, Newton, Almes et al 1983 | Database | Did not report primary outcomes
The South East London Screening Study Group 1977 | Database | Primary prevention
Specchia, De Servi, Scire et al 1996 | Reference list | No usual care arm
Stahle, Mattsson, Ryden et al 1999 | Database (Medline) | Evaluated interventions which were not comprehensive disease management systems
Starkey, Michaelis, Lusignan 2000 | Database | Not randomized
Stern and Cleary 1982 | Database | Evaluated interventions which were not comprehensive disease management systems
Strandberg, Pitkala, Berglind et al 2001 | Database (Embase) | Protocol only (no data presented)
Taddei, Galetta, Virdis et al 2000 | CMS | Evaluated interventions which were not comprehensive disease management systems
Thoresen, Friedman, Gill et al 1982 | Database | Not randomized
Townsend, Piper, Frank et al 1988 | Database | Evaluated interventions which were not comprehensive disease management systems
Tu, Pashos, Naylor et al 1997 | CMS | Not randomized
Vale, Jelinek, Best et al 2003 | Database (Medline) | Summary of trial already included
Van Drenth, Hulscher, Mokkink et al 1997 | Database | Not randomized
Vedin, Wilhelmsson, Tibblin et al 1976 | Database | Not randomized
Von Birgelen, Hartmann, Mintz et al 2003 | CMS | Not randomized
Wallner, Watzinger, Lindschinger et al 1999 | Database (Medline) | No usual care arm
Wasson, Gaudette, Whaley et al 1992 | Database | Evaluated interventions which were not comprehensive disease management systems
Waters, Higginson, Gladstone et al 1994 | CMS | Drug interventions
Weber, Barnard, Roy 1983 | CMS | Population not CHD
Weidner, Pischke, Eller 2003 | CMS | Abstract
Weinberger, Smith, Katz et al 1988 | Database | Did not report the outcomes for patients with CHD separately
Weingarten, Reidinger, Conner et al 1994 | Database | Inpatient-based intervention
Weintraub, Clements, Crisco et al 2003 | CMS | Not randomized
Williams, Paton, Siegler et al 2000 | CMS | Not randomized
Woollard, Burke, Beilin et al (Journal of Cardiovascular Risk) 2003 | Database (Medline) | Did not report the outcomes for patients with CHD separately
Woollard, Burke, Beilin (Journal of Human Hypertension) 2003 | Database (WOS) | Did not report the outcomes for patients with CHD separately
Yu-Poth, Zhao, Etherton et al 1999 | CMS | Guideline/review article

## Full Citations for Excluded Studies

Ades PA, Coello CE. Effects of exercise and cardiac rehabilitation on cardiovascular outcomes. Med Clin North Am. Jan. 2000;84(1):251-65. x. xi. [pmid: 10685138].
Akosah KO, Schaper AM, Havlik P, Barnhart S, Devine S. Improving care for patients with chronic heart failure in the community. The importance of a disease management program. Chest. 2002;122:906-12. [pmid: 12226031].
Aldana SG, Whitmer WR, Greenlaw R, Avins AL, Salberg A, Barnhurst M, et al. Cardiovascular risk reductions associated with aggressive lifestyle modification and cardiac rehabilitation. Heart Lung. Nov–Dec. 2003;32(6):374-82. [pmid: 14652529].
Ammerman AS, Keyserling TC, Atwood JR, Hosking JD, Zayed H, Krasny C. A randomized controlled trial of a public health nurse directed treatment program for rural patients with high blood cholesterol. Prev Med. Mar. 2003;36(3):340-51. [pmid: 12634025].
Angerer P, Siebert U, Kothny W, Muhlbauer D, Mudra H, von Schacky C. Impact of social support, cynical hostility and anger expression on progression of coronary atherosclerosis. J Am Coll Cardiol. Nov. 15. 2000;36(6):1781-8. [pmid: 11092644].
The Roman coronary heart disease prevention program. Final results. Giornale Italiano di Cardiologia. 1982;12:541-54. [pmid: 7169153].
Ariyo AA, Haan M, Tangen CM, Rutledge JC, Cushman M, Dobs A, et al. Depressive symptoms and risks of coronary heart disease and mortality in elderly Americans. Cardiovascular Health Study Collaborative Research Group. Circulation. Oct. 10. 2000;102(15):1773-9. [pmid: 11023931].
Arthur HM, Daniels C, McKelvie R, Hirsh J, Rush B. Effect of a preoperative intervention on preoperative and postoperative outcomes in low-risk patients awaiting elective coronary artery bypass graft surgery. A randomized, controlled trial. Ann Intern Med. Aug. 15. 2000;133(4):253-62. [pmid: 10929164].
Barnard RJ, Massey MR, Cherny S, O’Brien LT, Pritikin N. Long-term use of a high-complex-carbohydrate, high-fiber, low-fat diet and exercise in the treatment of NIDDM patients. Diabetes Care. May–Jun. 1983;6(3):268-73. [pmid: 6307614].
Barnes VA, Treiber FA, Turner JR, Davis H, Strong WB. Acute effects of transcendental meditation on hemodynamic functioning in middle-aged adults. Psychosom Med. Jul–Aug. 1999;61(4):525-31. [pmid: 10443761].
Bartels C, Gerdes A, Babin-Ebell J, Beyersdorf F, Boeken U, Doenst T, et al. Working Group on Extracorporeal Circulation and Mechanical Ventricular Assist Devices of the German Society for Thoracic and Cardiovascular Surgery. Cardiopulmonary bypass: Evidence or experience based?. J Thorac Cardiovasc Surg. Jul. 2002;124(1):20-7. [pmid: 12091804].
Beckie T. A supportive-educative telephone program: Impact on knowledge and anxiety after coronary artery bypass graft surgery. Heart Lung. 1989;18:46-55. [pmid: 2783580].
Bennett P, Blackall M, Clapham M, Little S, Player D, Williams K. South Birmingham Coronary Prevention Project: a district approach to the prevention of heart disease. Community Medicine. 1989;11:90-6. [pmid: 2752725].
Bentsson K. Rehabilitation after myocardial infarction. A controlled study. Scan J Rehab Med. 1983;15:1-9.
Berglund G, Nilsson P, Ericksson KF, et al. Long-term outcome of the Malmo preventive project: mortality and cardiovascular morbidity. J Intern Med. 2000;247:19-29. [pmid: 10672127].
Berkman LF, Blumenthal J, Burg M, Carney RM, Catellier D, Cowan MJ, et al. Enhancing Recovery in Coronary Heart Disease Patients Investigators (ENRICHD). Effects of treating depression and low perceived social support on clinical events after myocardial infarction: the Enhancing Recovery in Coronary Heart Disease Patients (ENRICHD) Randomized Trial. JAMA. Jun. 18. 2003;289(23):3106-16. [pmid: 12813116].
Bethell HJ, Mullee MA. A controlled trial of community based coronary rehabilitation. Br Heart J. 1990;64:370-5. [pmid: 2271343].
Billings JH, Scherwitz LW, Sullivan R, Sparler S, Ornish DM. Group support therapy in the Lifestyle Heart Trial. Scheidt S, Allan R, editors. Heart and Mind: The Emergence of Cardiac Psychology. Washington, DC. American Psychological Association. 1996:233-52.
Bjarnason-Wehrens B, Benesch L, Bischoff KO, Buran-Kilian B, Gysan D, Hollenstein U, et al. Effects of a Phase Ii Cardiac Rehabilitation Program Performed on an Outpatient Basis. Herz. Aug. 2003;28(5):404-412. [pmid: 12928739].
Blair TP, Bryant FJ, Bocuzzi S. Treatment of hypercholesterolemia by a clinical nurse using a stepped-care protocol in a non-volunteer population. Arch Intern Med. 1988;148:1046-8. [pmid: 3365075].
Blumenthal JA, Jiang W, Babyak MA, Krantz DS, Frid DJ, Coleman RE, et al. Stress management and exercise training in cardiac patients with myocardial ischemia. Effects on prognosis and evaluation of mechanisms. Arch Intern Med. Oct. 27. 1997;157(19):2213-23. [pmid: 9342998].
Bogden PE, Koontz LM, Williamson P, Abbott RD. The physician and pharmacist team. An effective approach to cholesterol reduction. J Gen Intern Med. 1997;12:158-64. [pmid: 9100140].
Boulay P, Prud’homme D. Health-Care Consumption and Recurrent Myocardial Infarction After 1 Year of Conventional Treatment Versus Short- and Long-Term Cardiac Rehabilitation. Preventive Medicine. May. 2004;38(5):586-593. [pmid: 15066361].
Bramlet DA, King H, Young L, Witt JR, Stoukides CA, Kaul AF. Management of hypercholesterolemia: practice patterns for primary care providers and cardiologists. Am J Cardiol. 1997;80(8B):39H-44H. [pmid: 9205017].
Brown BG, Zhao XQ, Chait A, Fisher LD, Cheung MC, Morse JS, et al. Simvastatin and niacin, antioxidant vitamins, or the combination for the prevention of coronary disease. N Engl J Med. Nov. 29. 2001;345(22):1583-92. [pmid: 11757504].
Burell G. Behavioral medicine interventions in secondary prevention of coronary heart disease. Orth-Gomer K, Schneiderman N, editors. Behavioral Medicine Approaches to Cardiovascular Disease Prevention. 1996:227-236.
Cambien F, Richard JL, Ducimetiere P, Warnet JM, Kahn J. The Paris Cardiovascular Risk Factor Prevention Trial. Effects of two years of intervention in a population of young men. J Epid Comm Health. 1981;35:91-7.
Campbell NC, Ritchie LD, Thain J, Deans HG, Rawles JM, Squair JL. Secondary prevention in coronary heart disease: a randomised trial of nurse led clinics in primary care. Heart. Nov. 1998;80(5):447-52. [pmid: 9930042].
Cannon CP, Braunwald E, McCabe CH, Rader DJ, Rouleau JL, Belder R, et al. Intensive versus moderate lipid lowering with statins after acute coronary syndromes. N Engl J Med. Apr. 8. 2004;350(15):1495-504. [pmid: 15007110].
Caracciolo EA, Davis KB, Sopko G, Kaiser GC, Corley SD, Schaff H, et al. Comparison of surgical and medical group survival in patients with left main coronary artery disease. Long-term CASS experience. Circulation. May. 1. 1995;91(9):2325-34. [pmid: 7729018].
Carlson JJ, Johnson JA, Franklin BA, Vanderlaan RL. Program Participation, Exercise Adherence, Cardiovascular Outcomes, and Program Cost of Traditional Versus Modified Cardiac Rehabilitation. American Journal of Cardiology. Jul. 1. 2000;86(1):17-23. [pmid: 10867086].
Carney RM, Blumenthal JA, Stein PK, Watkins L, Catellier D, Berkman LF, et al. Depression, heart rate variability, and acute myocardial infarction. Circulation. Oct. 23. 2001;104(17):2024-8. [pmid: 11673340].
Castillo-Richmond A, Schneider RH, Alexander CN, Cook R, Myers H, Nidich S, et al. Effects of stress reduction on carotid atherosclerosis in hypertensive African Americans. Stroke. Mar. 2000;31(3):568-73. [pmid: 10700487].
Chinaglia A, Gaschino G, Asteggiano R, Titta G, Gullstrand R, Bobbio M, et al. Impact of a nurse-based heart failure management program on hospitalization rate, functional status, quality of life, and medical costs. Ital Heart J. 2002;3:532-8. [pmid: 12407851].
Clark MA, Bakhai A, Lacey MJ, Pelletier EM, Cohen DJ. Clinical and economic outcomes of percutaneous coronary interventions in the elderly: an analysis of medicare claims data. Circulation. Jul. 20. 2004;110(3):259-64. [pmid: 15226211].
Coleman EA, Grothaus LC, Sandhu N, Wagner EH. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults. J Am Geriatr Soc. 1999;47:775-83. [pmid: 10404919].
Corti R, Fuster V, Fayad ZA, Worthley SG, Helft G, Smith D, et al. Lipid lowering by simvastatin induces regression of human atherosclerotic lesions: two years’ follow-up by high-resolution noninvasive magnetic resonance imaging. Circulation. Dec. 3. 2002;106(23):2884-7. [pmid: 12460866].
Coull AJ, Taylor VH, Elton R, Murdoch PS, Hargreaves AD. A randomised controlled trial of senior Lay Health Mentoring in older people with ischaemic heart disease: The Braveheart Project. Age Ageing. Jul. 2004;33(4):348-54. [pmid: 15136288].
Council on Clinical Cardiology and Council on Nutrition, Physical Activity and Metabolism. Exercise and physical activity in the prevention and treatment of atherosclerotic cardiovascular disease: a statement from the Council on Clinical Cardiology (Subcommittee on Exercise, Rehabilitation, and Prevention) and the Council on Nutrition, Physical Activity, and Metabolism (Subcommittee on Physical Activity). Circulation. Jun. 24. 2003;107(24):3109-16. [pmid: 12821592].
Cummings JE, Hughes SL, Weaver FM, et al. Cost-effectiveness of Veterans Administration hospital-based home care. Arch Intern Med. 1990;150:1274-80. [pmid: 2112906].
Cundiff DK. Coronary artery bypass grafting (CABG): reassessing efficacy, safety, and cost. MedGenMed. Jun. 19. 2002;4(2):7. [pmid: 12145567].
DeBusk RF, Haskell WL, Miller NH, Berra K, Taylor CB, Berger WE, et al. Medically directed at-home rehabilitation soon after clinically uncomplicated acute myocardial infarction: a new model for patient care. Am J Cardiol. 1985;55:251-7. [pmid: 3969859].
Debusk RF, Miller NH, Parker KM, Bandura A, Kraemer HC, Cher DJ, et al. Care Management for Low-Risk Patients With Heart Failure - a Randomized, Controlled Trial. Annals of Internal Medicine. Oct. 19. 2004;141(8):606-613. [pmid: 15492340].
de Lorgeril M, Salen P, Martin JL, Monjaud I, Delaye J, Mamelle N. Mediterranean diet, traditional risk factors, and the rate of cardiovascular complications after myocardial infarction: final report of the Lyon Diet Heart Study. Circulation. Feb. 16. 1999;99(6):779-85. [pmid: 9989963].
Denollet J, Brutsaert DL. Reducing emotional distress improves prognosis in coronary heart disease: 9-year mortality in a clinical trial of rehabilitation. Circulation. Oct. 23. 2001;104(17):2018-23. [pmid: 11673339].
Detry JMR, Vierendeel IA, Vanbutsele RJ, Robert AR. Early Short-Term Intensive Cardiac Rehabilitation Induces Positive Results as Long as One Year After the Acute Coronary Event: a Prospective One-Year Controlled Study. Journal of Cardiovascular Risk. Dec. 2001;8(6):355-361. [pmid: 11873091].
DeVries A, Day B, Scott D. Financial impact of the Dr. Dean Ornish program for reversing heart disease. Medical Management Analysis; Highmark Blue Cross Blue Shield. June. 2003.
DeVries A, Palmer A, Scheib C, Day B, Bennett S, Fetterolf D, et al. Financial impact of the Dr. Dean Ornish program for reversing heart disease. Medical Management Analysis; Highmark Blue Cross Blue Shield. February. 14. 2002;4(3).
Diehl HA. Coronary risk reduction through intensive community-based lifestyle intervention: the Coronary Health Improvement Project (CHIP) experience. Am J Cardiol. Nov. 26. 1998;82(10B):83T-87T.
Dugan E, Cohen SJ. Improving physicians’ implementation of clinical practice guidelines: enhancing primary care practice. Shumaker SA, Schron EB, Ockene JK, McBee WL, editors. The handbook of health behavior change. second edition. Springer Publishing Company. 1998:283-304.
Dugmore LD, Tipson RJ, Phillips MH, Flint EJ, Stentiford NH, Bone MF, et al. Changes in cardiorespiratory fitness, psychological wellbeing, quality of life, and vocational status following a 12 month cardiac exercise rehabilitation programme. Heart. 1999;81:359-66. [pmid: 10092561].
Eaker ED, Sullivan LM, Kelly-Hayes M, D’Agostino RB Sr, Benjamin EJ. Anger and hostility predict the development of atrial fibrillation in men in the Framingham Offspring Study. Circulation. Mar. 16. 2004;109(10):1267-71. [pmid: 14993133].
Eddy DM. Assessment of intensive lifestyle changes for the treatment of coronary heart disease. July. 12. 2000.
Ellingsen I, Hjermann I, Abdelnoor M, Hjerkinn EM, Tonstad S. Dietary and antismoking advice and ischemic heart disease mortality in men with normal or high fasting triacylglycerol concentrations: a 23-y follow-up study. American Journal of Clinical Nutrition. Nov. 2003;78(5):935-40. [pmid: 14594779].
Elliott-Eller M, Weidner G, Pischke C, Marlin R, Li M, Mendell N, et al. Clinical events in heart disease patients with low left ventricular ejection fraction: 3 year follow-up results. Proceedings of the International Academy of Cardiology, 3rd World Congress on Heart Disease – New trends in Research, Diagnosis and Treatment. 2003 July. Washington DC, USA.
Engblom E, Korpilahti K, Hamalainen H, Ronnemaa T, Puukka P. Quality of life and return to work 5 years after coronary artery bypass surgery. Long-term results of cardiac rehabilitation. J Cardiopulm Rehabil. 1997;17:29-36. [pmid: 9041068].
Esposito K, Giugliano D, Nappo F, Marfella R. Campanian Postprandial Hyperglycemia Study Group. Regression of carotid atherosclerosis by control of postprandial hyperglycemia in type 2 diabetes mellitus. Circulation. Jul. 13. 2004;110(2):214-9. Epub 2004 Jun 14. [pmid: 15197140].
Esselstyn CB Jr. Updating a 12-year experience with arrest and reversal therapy for coronary heart disease (an overdue requiem for palliative cardiology). Am J Cardiol. Aug. 1. 1999;84(3):339-41. A8. [pmid: 10496449].
Family Heart Study Group. Randomised controlled trial evaluating cardiovascular screening and intervention in general practice: principal results of British family heart study. BMJ. 1994;308:313-20. [pmid: 8124121].
Fields JZ, Walton KG, Schneider RH, Nidich S, Pomerantz R, Suchdev P, et al. Effect of a multimodality natural medicine program on carotid atherosclerosis in older subjects: a pilot trial of Maharishi Vedic Medicine. Am J Cardiol. Apr. 15. 2002;89(8):952-8. [pmid: 11950434].
Flanagan DE, Cox P, Paine D, Davies J, Armitage M. Secondary prevention of coronary heart disease in primary care: a healthy heart initiative. QJM. 1999;92:245-50. [pmid: 10615479].
Frasure-Smith N, Prince R. The ischemic heart disease life stress monitroing program: impact on mortality. Psychosomatic Med. 1985;47:431-45.
Frasure-Smith N, Lesperance F, Gravel G, Masson A, Juneau M, Talajic M, et al. Social support, depression, and mortality during the first year after myocardial infarction. Circulation. Apr. 25. 2000;101(16):1919-24. [pmid: 10779457].
Friedman M, Thoreson C, Gill J, et al. Alteration of type A behavior and reduction in cardiac recurrences in post-myocardial infarction patients. Am Heart J. 1984;108:237-48. [pmid: 6464961].
Galatius S, Gustafsson F, Kistorp CM, Nielsen PH, Atar D, Hildebrandt PR. Establishment of a nurse-led heart failure clinic. Design and baseline data from the first two years. Ugeskr Laeger. 2003;165:686-90. [pmid: 12617047].
Geil PB, Anderson JW, Gustafson NJ. Women and men with hypercholesterolemia respond similarly to an American Heart Association step 1 diet. J Am Diet Assoc. Apr. 1995;95(4):436-41. [pmid: 7699185].
George BJ, Goldberg N. The benefits of exercise in geriatric women. Am J Geriatr Cardiol. Sep–Oct. 2001;10(5):260-3. [pmid: 11528284].
Ghoncheh S, Smith JC. Progressive muscle relaxation, yoga stretching, and ABC relaxation theory. J Clin Psychol. Jan. 2004;60(1):131-6. [pmid: 14692015].
Gielen S, Schuler G, Hambrecht R. Exercise training in coronary artery disease and coronary vasomotion. Circulation. Jan. 2. 2001;103(1):E1-6. [pmid: 11136704].
Gleason JA, Bourdet KL, Koehn K, Holay SY, Schaefer EJ. Cardiovascular risk reduction and dietary compliance with a home-delivered diet and lifestyle modification program. J Am Diet Assoc. Oct. 2002;102(10):1445-51. [pmid: 12396164].
Gould KL, Ornish D, Kirkeeide R, Brown S, Stuart Y, Buchi M, et al. Improved stenosis geometry by quantitative coronary arteriography after vigorous risk factor modification. Am J Cardiol. Apr. 1. 1992;69(9):845-53. [pmid: 1550011].
Gould KL, Ornish D, Scherwitz L, Brown S, Edens RP, Hess MJ, et al. Changes in myocardial perfusion abnormalities by positron emission tomography after long-term, intense risk factor modification. JAMA. Sep. 20. 1995;274(11):894-901. [pmid: 7674504].
Grimm RH Jr. for the MRFIT. The Multiple Risk Factor Intervention Trial in the US. A summary of results at four years in special intervention and usual care men. Preventive Medicine. 1983;12:185-90. [pmid: 6844303].
Grundy SM, Cleeman JI, Merz CN, Brewer HB Jr, Clark LT, Hunninghake DB, et al. National Heart, Lung, and Blood Institute; American College of Cardiology Foundation; American Heart Association. Implications of recent clinical trials for the National Cholesterol Education Program Adult Treatment Panel III guidelines. Circulation. Jul. 13. 2004;110(2):227-39. [pmid: 15249516].
Gulati M, Pandey DK, Arnsdorf MF, Lauderdale DS, Thisted RA, Wicklund RH, et al. Exercise capacity and the risk of death in women: the St James Women Take Heart Project. Circulation. Sep. 30. 2003;108(13):1554-9. [pmid: 12975254].
Hakim AA, Curb JD, Petrovitch H, Rodriguez BL, Yano K, Ross GW, et al. Effects of walking on coronary heart disease in elderly men: the Honolulu Heart Program. Circulation. Jul. 6. 1999;100(1):9-13. [pmid: 10393674].
Hambrecht R, Walther C, Mobius-Winkler S, Gielen S, Linke A, Conradi K, et al. Percutaneous coronary angioplasty compared with exercise training in patients with stable coronary artery disease: a randomized trial. Circulation. Mar. 23. 2004;109(11):1371-8. Epub 2004 Mar 08. [pmid: 15007010].
Harris DE, Record NB, Gipson GW, Pearson TA. Lipid lowering in a multidisciplinary clinic compared with primary physician management. Am J Cardiol. 1998;81:929-33. [pmid: 9555787].
Hedback B, Perk J. 5-year results of a comprehensive rehabilitation programme after myocardial infarction. Eur Heart J. 1987;8:234-42. [pmid: 3582382].
Imperial Cancer Research Fund OXCHECK Study Group. Effectiveness of health checks conducted by nurses in primary care: final results of the OXCHECK Study. BMJ. 1995;310:1099-1104. [pmid: 7742676].
Jain SC, Uppal A, Bhatnagar SO, Talukdar B. A study of response pattern of non-insulin dependent diabetics to yoga therapy. Diabetes Res Clin Pract. Jan. 1993;19(1):69-74. [pmid: 8472621].
Jukema JW, Bruschke AV, van Boven AJ, Reiber JH, Bal ET, Zwinderman AH, et al. Effects of lipid lowering by pravastatin on progression and regression of coronary artery disease in symptomatic men with normal to moderately elevated serum cholesterol levels. The Regression Growth Evaluation Statin Study (REGRESS). Circulation. May. 15. 1995;91(10):2528-40. [pmid: 7743614].
Kawachi I, Sparrow D, Vokonas PS, Weiss ST. Symptoms of anxiety and risk of coronary heart disease. The Normative Aging Study. Circulation. Nov. 1994;90(5):2225-9. [pmid: 7955177].
Ketola E, Makela M, Klockars M. Individualised Multifactorial Lifestyle Intervention Trial for High-Risk Cardiovascular Patients in Primary Care. British Journal of General Practice. Apr. 2001;51(465):291-294. [pmid: 11458482].
Koertge J, Weidner G, Billings JH, Elliott-Eller M, Lipsenthal L, Merritt-Worden T, et al. Medical and psychosocial characteristics of CHD patients in the Multicenter Lifestyle Demonstration Project: Results from a 1-year follow-up [Abstract]. Psychosomatic Medicine. 2002;64:85-174.
Koertge J, Weidner G, Elliott-Eller M, Scherwitz L, Merritt-Worden TA, Marlin R, et al. Improvement in medical risk factors and quality of life in women and men with coronary artery disease in the Multicenter Lifestyle Demonstration Project. Am J Cardiol. Jun. 1. 2003;91(11):1316-22. [pmid: 12767423].
Kornitzer M, De Backer G, Dramaix M, Thilly C. The Belgian Heart Disease Prevention Project. Modification of the coronary risk profile in an industrial population. Circulation. 1980;61:18-25. [pmid: 7349932].
Krachler M, Lindschinger M, Eber B, Watzinger N, Wallner S. Trace elements in coronary heart disease: Impact of intensified lifestyle modification. Biol Trace Elem Res. Dec. 1997;60(3):175-85. [pmid: 9494056].
Kris-Etherton PM, Harris WS, Appel LJ. American Heart Association. Nutrition Committee. Fish consumption, fish oil, omega-3 fatty acids, and cardiovascular disease. Circulation. Nov. 19. 2002;106(21):2747-57. [pmid: 12438303].
Lampert R, Joska T, Burg MM, Batsford WP, McPherson CA, Jain D. Emotional and physical precipitants of ventricular arrhythmia. Circulation. Oct. 1. 2002;106(14):1800-5. [pmid: 12356633].
Lear SA, Ignaszewski A, Linden W, Brozic A, Kiess M, Spinelli JJ, et al. A randomized controlled trial of an extensive lifestyle management intervention (ELMI) following cardiac rehabilitation: study design and baseline data. Curr Control Trials Cardiovasc Med. Nov. 12. 2002;3(1):9. [pmid: 12473163].
Lesperance F, Frasure-Smith N, Talajic M, Bourassa MG. Five-year risk of cardiac mortality in relation to initial severity and one-year changes in depression symptoms after myocardial infarction. Circulation. Mar. 5. 2002;105(9):1049-53. [pmid: 11877353].
Lewin RJ, Furze G, Robinson J, Griffith K, Wiseman S, Pye M, et al. A randomised controlled trial of a self-management plan for patients with newly diagnosed angina. Br J Gen Pract. Mar. 2002;52(476):194-6. 199. 201. [pmid: 12030661].
Lewis CE, Resnik BA. Nurse clinics and progressive ambulatory patient care. N Engl J Med. 1967;277:1236-41. [pmid: 6058613].
Liao XX, Ma H, Dong YG, Tang AL, Tao J, Yang XQ. Effects of early rehabilitative intervention on heart rate variability and quality of life in patients with uncomplicated acute myocardial infarction. Zhonghua Linchuang Kangfu Zazhi. 2003;7(21):2934-2935.
Lichtenstein AH, Van Horn L. Very low fat diets. Circulation. Sep. 1. 1998;98(9):935-9. [pmid: 9738652].
Lindholm LH, Ekbom T, Dash C, Eriksson M, Tibblin G, Schersten B. on behalf of the CELL Study Group. The impact of health care advice given in primary care on cardiovascular risk. BMJ. 1995;310:1105-9. [pmid: 7742677].
Maggioni AP. Secondary prevention: improving outcomes following myocardial infarction. Heart. Sep. 2000;84(Suppl 1):i5-7. discussion i50. [pmid: 10956310].
Malach M, Imperato PJ. Depression and acute myocardial infarction. Prev Cardiol. Spring. 2004;7(2):83-90. [pmid: 15133376].
Marra S, Paolillo V, Spadaccini F, Angelino PF. Long-term follow-up after a controlled randomized post-myocardial infarction rehabilitation programme: effects on morbidity and mortality. Eur Heart J. 1985;6:656-63. [pmid: 4054135].
Marshall J, Penckofer S, Llewellyn J. Structured postoperative teaching and knowledge and compliance of patients who had coronary artery bypass surgery. Heart Lung. 1986;15:76-82. [pmid: 3484735].
Matthews KA, Gump BB, Harris KF, Haney TL, Barefoot JC. Hostile behaviors predict cardiovascular mortality among men enrolled in the Multiple Risk Factor Intervention Trial. Circulation. Jan. 6. 2004;109(1):66-70. [pmid: 14662707].
Meer H. Coronary heart disease health improvement programme. Final report. Barking and Havering Health Authority, Romford (United Kingdom). Directorate of Public Health. Oct. 1999:67. Available from British Library Document Supply Centre-DSC:6966.200(120). Public health research report No. 120.
Meland E, Laerum E, Ulvik RJ. Effectiveness of two preventive interventions for coronary heart disease in primary care. Scand J Prim Health Care. 1997;15:57-64. [pmid: 9101627].
Merritt TA, Scherwitz LW, Brown SE, Billings JH, Armstrong WT, Sparler SL, et al. Changes in lifestyle and exercise capacity. Journal of Cardiopulmonary Rehabilitation. 1990;10(9):354.
Merritt T, Ornish D, Scherwitz L, Billings J, Elliott L, Lipsenthal L, et al. Effects of intensive lifestyle changes on coronary heart disease risk factors and clinical status in self-selected heart patients. Journal of Cardiopulmonary Rehabilitation. 1995;15(5):353.
Merritt T, Ornish D, Scherwitz L, Billings J, Elliott L, Lipsenthal L, et al. Preliminary results from the multicenter lifestyle trial: Can self-selected heart patients maintain intensive lifestyle changes?. Journal of Cardiopulmonary Rehabilitation. 1995;15(5):354.
Merritt-Worden TA, Pettengill EB, Ornish D. Gender comparisons in an intensive comprehensive risk factor reduction program [Abstract]. Journal of Cardiopulmonary Rehabilitation. 2003;23(5):376.
Miettinen TA, Pyorala K, Olsson AG, Musliner TA, Cook TJ, Faergeman O, et al. Cholesterol-lowering therapy in women and elderly patients with myocardial infarction or angina pectoris: findings from the Scandinavian Simvastatin Survival Study (4S). Circulation. Dec. 16. 1997;96(12):4211-8. [pmid: 9416884].
Miller ER 3rd, Erlinger TP, Young DR, Jehn M, Charleston J, Rhodes D, et al. Results of the Diet, Exercise, and Weight Loss Intervention Trial (DEW-IT). Hypertension. Nov. 2002;40(5):612-8. [pmid: 12411452].
Mittleman MA, Maclure M, Sherwood JB, Mulry RP, Tofler GH, Jacobs SC, et al. Triggering of acute myocardial infarction onset by episodes of anger. Determinants of Myocardial Infarction Onset Study Investigators. Circulation. Oct. 1. 1995;92(7):1720-5. [pmid: 7671353].
National Cholesterol Education Program (NCEP). Detection, evaluation, and treatment of high blood cholesterol in adults (adult treatment panel III). Final Report. Third Report of the National Cholesterol Education Program (NCEP), National Heart, Lung, and Blood Institute, National Institutes of Health. NIH Publication No. 02–5215. September. 2002.
Ness AR, Hughes J, Elwood PC, Whitley E, Smith GD, Burr ML. The long-term effect of dietary advice in men with coronary disease: follow-up of the Diet and Reinfarction trial (DART). European Journal of Clinical Nutrition. Jun. 2002;56(6):512-8. [pmid: 12032650].
Nicholson AS, Sklar M, Barnard ND, Gore S, Sullivan R, Browning S. Toward improved management of NIDDM: A randomized, controlled, pilot intervention using a lowfat, vegetarian diet. Prev Med. Aug. 1999;29(2):87-91. [pmid: 10446033].
Oldenburg B, Martin A, Greenwood J, Bernstein L, Allan R. A controlled trial of a behavioral and educational intervention following coronary artery bypass surgery. J Cardiopulmonary Rehabil. 1995;15:39-46. [pmid: 8529086].
Ornish D. Avoiding revascularization with lifestyle changes: The Multicenter Lifestyle Demonstration Project. Am J Cardiol. Nov. 26. 1998;82(10B):72T-76T. [pmid: 9671012].
Ornish D. Statins and the soul of medicine. American Journal of Cardiology. 2002;89(1):1286-90. [pmid: 12031729].
Ornish DM, Pettengill EB. Marked improvements in biomedical and psychosocial cardiac risk factors from a community-based lifestyle change program. Proceedings of the Annual Meeting of the American Heart Association. 2003.
Ornish D. Concise Review: intensive lifestyle changes in the management of coronary heart disease. Concise review related to chapter 241: the pathogenesis of atherosclerosis. Printed from Harrison’s Online (www.harrisononline.com). McGraw-Hill Companies. 2001–2004. http://www.accessmedicine.com/server-java/arknoid/amed/harrisons/ex_editorials/ed1209... accessed 09 Dec 2004.
Ornish D. Intensive life-style changes in the management of coronary heart disease (chapter 8). Braunwald E. Harrison’s Advances in Cardiology. New York. McGraw Hill. 2002.
Ornish D, Hart JA. Intensive Risk Factor Modification. Hennekens C, Manson J, editors. Clinical Trials in Cardiovascular Disease. Boston. W.B. Sanders. 1998.
Pater C, Ditlef Jacobsen C, Rollag A, Sandvik L, Erikssen J, Karin Kogstad E. Design of a randomized controlled trial of comprehensive rehabilitation in patients with myocardial infarction, stabilized acute coronary syndrome, percutaneous transluminal coronary angioplasty or coronary artery bypass grafting: Akershus Comprehensive Cardiac Rehabilitation Trial (the CORE Study). Curr Control Trials Cardiovasc Med. 2000;1(3):177-183. [pmid: 11714435].
Peiss B, Kurleto B, Rubenfire M. Physicians and nurses can be effective educators in coronary risk reduction. J Gen Intern Med. 1995;10:77-81. [pmid: 7730943].
Pettengill EB, Pearson J, Pifalo B, Wilhelm A, Lipsenthal L, Merritt T, et al. Community-based lifestyle change program produces substantial reductiosn in biomedical and psychosocial cardiac risk factors. 4th Scientific Forum on Quality of Care and Outcomes Research in Cardiovascular Disease and Stroke. October 13–14 2002. Washington, DC.
Pfisterer M, Buser P, Osswald S, Allemann U, Amann W, Angehrn W, et al. Trial of Invasive versus Medical therapy in Elderly patients (TIME) Investigators. Outcome of elderly patients with chronic symptomatic coronary artery disease with an invasive vs optimized medical treatment strategy: one-year results of the randomized TIME trial. JAMA. Mar. 5. 2003;289(9):1117-23. [pmid: 12622581].
Picard MH, Schwartz DC, Ahn DK, Kraemer HC, Berger WE, Blumberg R, et al. Cost-benefit analysis of early return to work after uncomplicated acute myocardial infarction. Am J Cardiol. 1989;63:1308-14. [pmid: 2499172].
Pischke C, Weidner G, Billings J, Elliott-Eller M, Lipsenthal L, Merritt-Worden T, et al. Lifestyle changes among heart disease patients with diabetes: results from the multicenter lifestyle demonstration project. Proceedings of the 62nd Annual Meeting & Scientific Sessions of the American Diabetes Association. 2002 June 14–18. San Francisco, USA.
Pitt B, Waters D, Brown WV, van Boven AJ, Schwartz L, Title LM, et al. Aggressive lipid-lowering therapy compared with angioplasty in stable coronary artery disease. Atorvastatin versus Revascularization Treatment Investigators. N Engl J Med. Jul. 8. 1999;341(2):70-6. [pmid: 10395630].
Pollock ML, Franklin BA, Balady GJ, Chaitman BL, Fleg JL, Fletcher B, et al. AHA Science Advisory. Resistance exercise in individuals with and without cardiovascular disease: benefits, rationale, safety, and prescription: An advisory from the Committee on Exercise, Rehabilitation, and Prevention, Council on Clinical Cardiology, American Heart Association; Position paper endorsed by the American College of Sports Medicine. Circulation. Feb. 22. 2000;101(7):828-33. [pmid: 10683360].
Pozen MW, Stechmiller JA, Harris W, Smith S, Fried DD, Voigt GC. A nurse rehabilitator’s impact on patients with myocardial infarction. Medical Care. 1977;15:830-7. [pmid: 909325].
Prochaska JO, Johnson S, Lee P. The transtheoretical model of behavior change. Shumaker SA, Schron EB, Ockene JK, McBee WL, editors. The handbook of health behavior change. second edition. 59-84. Springer Publishing Company.
Pyke SDM, Wood DA, Kinmonth AL, Thompson SG. for the Family Heart Study Group. Change in coronary risk and coronary risk factor levels in couples following lifestyle intervention. Arch Fam Med. 1997;6:354-60. [pmid: 9225707].
Rahe RH, Ward HW, Hayes V. Brief group therapy in myocardial infarction rehabilitation: three- to four-year follow-up of a controlled trial. Psychosomatic Med. 1979;41:229. -.
Rihal CS, Raco DL, Gersh BJ, Yusuf S. Indications for coronary artery bypass surgery and percutaneous coronary intervention in chronic stable angina: review of the evidence and methodological considerations. Circulation. Nov. 18. 2003;108(20):2439-45. [pmid: 14623791].
Roderick P, Ruddock V, Hunt P, Miller G. A randomized trial to evaluate the effectiveness of dietary advice by practice nurses in lowering diet-related coronary heart disease risk. Br J Gen Pract. 1997;47:7-11. [pmid: 9115804].
Roman O, Gutierrez M, Luksic I, Chavez E, Camuzzi AL, Villalon E, et al. Cardiac rehabilitation after acute myocardial infarction. 9-year controlled follow-up study. Cardiology. 1983;70:223-31. [pmid: 6640562].
Rose G, Heller RF, Pedoe HT, Christie DGS. Heart disease prevention project: a randomised controlled trial in industry. BMJ. 1980;i:747-751. [pmid: 6989437].
Rubenstein LV, Kahn KL, Reinisch EJ, Sherwood MJ, Rogers WH, Kamberg C, et al. Changes in quality of care for five diseases measured by implicit review, 1981 to 1986. JAMA. Oct. 17. 1990;264(15):1974-9. [pmid: 2214062].
Ruo B, Rumsfeld JS, Hlatky MA, Liu H, Browner WS, Whooley MA. Depressive symptoms and health-related quality of life: the Heart and Soul Study. JAMA. Jul. 9. 2003;290(2):215-21. [pmid: 12851276].
[No authors listed]. Randomised trial of cholesterol lowering in 4444 patients with coronary heart disease: the Scandinavian Simvastatin Survival Study (4S). Lancet. Nov. 19. 1994;344(8934):1383-9. [pmid: 7968073].
Schectman G, Wolff N, Byrd JC, Hiatt JG, Hartz A. Physician extenders for cost-effective management of hypercholesterolemia. J Gen Intern Med. 1996;11:277-86. [pmid: 8725976].
Schneider RH, Staggers F, Alexander CN, Sheppard W, Rainforth M, Kondwani K, et al. A randomised controlled trial of stress reduction for hypertension in older African Americans. Hypertension. Nov. 1995;26(5):820-7. [pmid: 7591024].
Sdringola S, Nakagawa K, Nakagawa Y, Yusuf SW, Boccalandro F, Mullani N, et al. Combined intense lifestyle and pharmacologic lipid treatment further reduce coronary events and myocardial perfusion abnormalities compared with usual-care cholesterol-lowering drugs in coronary artery disease. J Am Coll Cardiol. Jan. 15. 2003;41(2):263-72. [pmid: 12535820].
Shaffer J, Wexler LF. Reducing low-density lipoprotein cholesterol levels in an ambulatory care system. Results of a multidisciplinary collaborative practice lipid clinic compared with traditional physician-based care. Arch Intern Med. 1995;155:2330-5. [pmid: 7487258].
Shintani TT, Beckham S, Brown AC, O’Connor HK. The Hawaii Diet: ad libitum high carbohydrate, low fat multi-cultural diet for the reduction of chronic disease risk factors: obesity, hypertension, hypercholesterolemia, and hyperglycemia. Hawaii Med J. Mar. 2001;60(3):69-73. [pmid: 11320614].
Simpson DR, Dixon BG, Bolli P. Effectiveness of Multidisciplinary Patient Counselling in Reducing Cardiovascular Disease Risk Factors Through Nonpharmacological Intervention: Results From the Healthy Heart Program. Canadian Journal of Cardiology. Feb. 2004;20(2):177-186. [pmid: 15010741].
Sivarajan ES, Newton KM, Almes MJ, Kempf TM, Mansfield LW, Bruce RA. Limited effects of outpatient teaching and counseling after myocardial infarction: a controlled study. Heart Lung. 1983;12:65-73. [pmid: 6549638].
The South-East London Screening Study Group. A controlled trial of multiphasic screening in middle-age: results of the South-East London Screening Study. Int J Epidemiol. 1977;6:357-63. [pmid: 608798].
Specchia G, De Servi S, Scire A, et al. Interaction between exercise training and ejection fraction in predicting prognosis after a first myocardial infarction. Circulation. 1996;94:978-82. [pmid: 8790035].
Stahle A, Mattsson E, Ryden L, Unden A, Nordlander R. Improved physical fitness and quality of life following training of elderly patients after acute coronary events. A 1 year follow-up randomized controlled study.[see comment]. European Heart Journal. Oct. 1999;20(20):1475-84. [pmid: 10493846].
Starkey C, Michaelis J, Lusignan S. Computerised systematic secondary prevention in ischemic heart disease: a study in one practice. Public Health. 2000;114:169-75. [pmid: 10878743].
Stern MJ, Cleary P. The national exercise and heart disease project. Long-term psychosocial outcome. Arch Intern Med. 1982;142:1093-7. [pmid: 7092423].
Strandberg TE, Pitkala K, Berglind S, Nieminen MS, Tilvis RS. Multifactorial cardiovascular disease prevention in patients aged 75 years and older: A randomized controlled trial: Drugs and Evidence Based Medicine in the Elderly (DEBATE) Study. Am Heart J. Dec. 2001;142(6):945-51. [pmid: 11717595].
Taddei S, Galetta F, Virdis A, Ghiadoni L, Salvetti G, Franzoni F, et al. Physical activity prevents age-related impairment in nitric oxide availability in elderly athletes. Circulation. Jun. 27. 2000;101(25):2896-901. [pmid: 10869260].
Thoresen CE, Friedman M, Gill JK, Ulmer DK. The recurrent coronary prevention project. Some preliminary findings. Acta Med Scand. 1982;660(Suppl):172-92.
Townsend J, Piper M, Frank AO, Dyer S, North WRS, Meade TW. Reduction in hospital readmission stay of elderly patients by a community based hospital discharge scheme: a randomized controlled trial. BMJ. 1988;297:544-7. [pmid: 2844356].
Tu JV, Pashos CL, Naylor CD, Chen E, Normand SL, Newhouse JP, et al. Use of cardiac procedures and outcomes in elderly patients with myocardial infarction in the United States and Canada. N Engl J Med. May. 22. 1997;336(21):1500-5. [pmid: 9154770].
Vale MJ, Jelinek MV, Best JD, Dart AM, Grigg LE, Hare DL, et al. COACH Study Group. Coaching patients On Achieving Cardiovascular Health (COACH): a multicenter randomized trial in patients with coronary heart disease. Arch Intern Med. Dec. 8ȓ22. 2003;163(22):2775-83. [pmid: 14662633].
Van Drenth BB, Hulscher EJL, Mokkink HGA, van de Lisdonk EH, van der Wouden JC, Grol RPTM. Effects of outreach visits by trained nurses on cardiovascular risk-factor recording in general practice. A controlled trial. Eur J Gen Pract. 1997;3:90-5.
Vedin A, Wilhelmsson C. Tibblin G, Wilhelmsen L. The postinfarction clinic in Goteborg, Sweden. Acta Med Scand. 1976;200:453-6. [pmid: 1015353].
von Birgelen C, Hartmann M, Mintz GS, Baumgart D, Schmermund A, Erbel R. Relation between progression and regression of atherosclerotic left main coronary artery disease and serum cholesterol levels as assessed with serial long-term (> or =12 months) follow-up intravascular ultrasound. Circulation. Dec. 2. 2003;108(22):2757-62. [pmid: 14623804].
Wallner S, Watzinger N, Lindschinger M, Smolle KH, Toplak H, Eber B, et al. Effects of intensified lifestyle modification on the need for further revascularization after coronary angioplasty.[see comment]. European Journal of Clinical Investigation. May. 1999;29(5):372-9. [pmid: 10354193].
Wasson J, Gaudette C, Whaley F, Sauvigne A, Baribeau P, Welch G. Telephone care as a substitute for routine clinic follow-up. JAMA. 1992;267:1788-93. [pmid: 1545464].
Waters D, Higginson L, Gladstone P, Kimball B, Le May M, Boccuzzi SJ, et al. Effects of monotherapy with an HMG-CoA reductase inhibitor on the progression of coronary atherosclerosis as assessed by serial quantitative arteriography. The Canadian Coronary Atherosclerosis Intervention Trial. Circulation. Mar. 1994;89(3):959-68. [pmid: 8124836].
Weber F, Barnard RJ, Roy D. Effects of a high-complex-carbohydrate, low-fat diet and daily exercise on individuals 70 years of age and older. J Gerontol. Mar. 1983;38(2):155-61. [pmid: 6827033].
Weidner G, Pischke C, Eller M, Ornish D. Clinical profile and outcome of heart disease patients with low LVEF: results from the Multicenter Lifestyle Demonstration Project. Presented at the annual meeting of the American Psychosomatic Society. Phoenix, AZ. March 5–8, 2003.
Weinberger M, Smith DM, Katz BP, Moore PS. The cost-effectiveness of intensive post-discharge care: a randomized trial. Med Care. 1988;26:1092-1102. [pmid: 2846971].
Weingarten S, Reidinger M, Conner L, Johnson B, Ellrodt AG. Reducing lengths of stay in the coronary care unit with a practice guideline for patients with congestive heart failure: Insights from a controlled clinical trial. Med Care. 1994;32:1232-43. [pmid: 7967861].
Weintraub WS, Clements SD Jr, Crisco LV, Guyton RA, Craver JM, Jones EL, et al. Twenty-year survival after coronary artery surgery: an institutional perspective from Emory University. Circulation. Mar. 11. 2003;107(9):1271-7. [pmid: 12628947].
Williams JE, Paton CC, Siegler IC, Eigenbrodt ML, Nieto FJ, Tyroler HA. Anger proneness predicts coronary heart disease risk: prospective analysis from the atherosclerosis risk in communities (ARIC) study. Circulation. May. 2. 2000;101(17):2034-9. [pmid: 10790343].
Woollard J, Burke V, Beilin LJ, Verheijden M, Bulsara MK. Effects of a general practice-based intervention on diet, body mass index and blood lipids in patients at cardiovascular risk. Journal of Cardiovascular Risk. Feb. 2003;10(1):31-40. [pmid: 12569235].
Woollard J, Burke V, Beilin LJ. Effects of General Practice-Based Nurse-Counselling on Ambulatory Blood Pressure and Antihypertensive Drug Prescription in Patients at Increased Risk of Cardiovascular Disease. Journal of Human Hypertension. Oct. 2003;17(10):689-695. [pmid: 14504627].
Yu-Poth S, Zhao G, Etherton T, Naglak M, Jonnalagadda S, Kris-Etherton PM. Effects of the National Cholesterol Education Program’s Step I and Step II dietary intervention programs on cardiovascular disease risk factors: a meta-analysis. Am J Clin Nutr. Apr. 1999;69(4):632-46. [pmid: 10197564].