# Search Strategies

## MEDLINE - Ovid Version: rel9.1.0

Searched December 16, 2004

Results: 2527 unique records

1. exp “Case Management”/
2. exp “Comprehensive Health Care”/
3. exp “Disease Management”/
4. exp “Health Services Research”/
5. exp “Home Care Services”/
6. exp “Clinical Protocols”/
7. exp “Patient Care Planning”/
8. exp “Quality of Health Care”/
9. exp REHABILITATION/
10. (nurse adj led adj1 clinic$).ti,ab.
11. (special$ adj1 clinic$).ti,ab.
12. or/1–11
13. exp “Myocardial Ischemia”/ or “Myocardial Ischemia$”.ti,ab.
14. RANDOMIZED CONTROLLED TRIAL.pt.
15. ANIMAL/ not HUMAN/
16. 14 not 15
17. 12 and 13 and 16
18. limit 17 to (english language and yr=1999 – 2005)
19. remove duplicates from 18

- The same search was conducted in EBM Reviews - Cochrane Central Register of Controlled Trials - Ovid Version: rel9.1.0 (4th Quarter 2004) on December 16, 2004.
- There were 141 unique results.

## PubMed

Searched December 16, 2004

Results: 50 unique records

The following search was conducted:

(“Case Management”[MeSH] OR “Comprehensive Health Care”[MeSH] OR “Disease Management”[MeSH] OR “Health Services Research”[MeSH] OR “Home Care Services”[MeSH] OR “Clinical Protocols”[MeSH] OR “Clinical Protocols”[MeSH] OR “Patient Care Planning”[MeSH] OR “Quality of Health Care”[MeSH] OR “Rehabilitation”[MeSH]) AND (“Myocardial Ischemia”[MeSH] OR Myocardial Ischemia Field: Title/Abstract)

Limits: Publication Date from 2004/01/01 to 2004/12/17, Randomized Controlled Trial

## Web of Science

Searched December 17, 2004

Results: 606 unique records

The Cited Reference Search feature was used to search for studies that cited the included studies from the original article.

## EMBASE - Ovid Version: rel9.1.0

1988 to 2004 Week 51

Searched December 20, 2004

Results: 1313 unique records

1. exp “Patient Care”/
2. exp “Health Care”/
3. exp “Disease Management”/
4. exp “Health Services Research”/
5. exp “Home Care”/
6. exp “Clinical Protocol”/
7. exp “Health Care Quality”/
8. exp REHABILITATION/
9. (nurse adj led adj1 clinic$).ti,ab.
10. (special$ adj1 clinic$).ti,ab.
11. or/1–10
12. exp “Heart Muscle Ischemia”/ or exp “Ischemic Heart Disease”/ or exp “Coronary Heart Disease”/ or “Myocardial Ischemia$”.ti,ab.
13. RANDOMIZED CONTROLLED TRIAL/
14. 11 and 12 and 13
15. limit 14 to english
16. limit 15 to human
17. remove duplicates from 16
18. limit 17 to yr=1999 – 2005

## CINAHL (Cumulative Index to Nursing & Allied Health Literature) - Ovid Version: rel9.1.0

1982 to December Week 2 2004

Searched December 21, 2004

Results: 9 unique records

1. exp “Case Management”/
2. *Health Care Delivery/
3. exp “Disease Management”/
4. exp “Health Services Research”/
5. exp Home Health Care/
6. exp Protocols/
7. exp “Quality of Health Care”/
8. exp REHABILITATION/
9. (nurse adj led adj1 clinic$).ti,ab.
10. (special$ adj1 clinic$).ti,ab.
11. or/1–10
12. exp “Myocardial Ischemia”/ or “Myocardial Ischemia$”.ti,ab.
13. clinical trial.pt.
14. animals/
15. 13 not 14
16. and/11–12,15
17. limit 16 to yr=1999–2005

## SIGLE - FIZ Karlsruhe – Version Interhost 3000

Searched December 21, 2004

Results: 53

CORONARY OR MYOCARDIAL

AND

Health services, health administration, community care services