# ACKNOWLEDGEMENTS

The authors gratefully acknowledge the help of Dr. N.C. Campbell (references 28 and 29), Dr. R. West (reference 46), Dr. M. Naylor (references 30, 31, and 50), Dr. N. Marchionni (reference 66), Drs. Vale and Sundararajan (reference 81), Dr. Otterstad and Ms. Peersen (reference 82), Dr. W. Young (reference 83), Drs. K. Jolly and J. Bell (reference 85), Dr. J.K. Allen (reference 51), Dr. T.G. Allison (references 52, 53), Dr. M.E. Cupples (reference 40, 45), Drs. R.F. De Busk et al. (via Dr. Taylor, reference 44), Dr. H. Hamalainen (reference 35), Dr. W.L. Haskell (reference 43), Dr. H. Higgins (reference 60), Dr. M. Johnston (reference 61), Dr. S. Lear (reference 62), Dr. J.H. Lichtman (via Dr. Krumholz, reference 63), Dr. J. Lisspers. (reference 64), Dr. S. Masley. (reference 65), Dr. F. McHugh (via Dr. G Lindsay, reference 67), Drs. P. Murchie and N Campbell (references 37 and 38), Dr. D. Ornish (references 70, 71, and 72), Dr. M. Stagmo. (reference 76), Dr. O. Sundin (via Dr. Lisspers, reference 78), and Dr. Toobert (reference 79) for providing further details about their studies and/or interventions.

The authors also thank the staff of the University of Alberta Evidence-based Practice Center who participated in generating this report: Carol Friesen (searching), John Russell (retrieving articles, administrative tasks), Marilyn Josefsson (retrieving articles, administrative tasks), Natasha Wiebe (screening), Michelle Tubman (screening), Kenneth Bond (kappa calculations).

The authors also thank those who assisted in undertaking the survey of primary study authors: Sue Lissel (screening, survey data extraction and collation of results), Jessica McNeill (identification of author contact information), Stephanie Heath, and Nicole Freydberg (presentation of results).