# SCOPE OF REPORT

The Centers for Medicare and Medicaid Services (CMS) requested that AHRQ commission an evidence report to assist CMS and the Medicare Coverage Advisory Committee in considering treatments for nonunion fractures. On June 16th 2005, AHRQ issued a Statement of Work (SOW) contracting ECRI to prepare a report on the role of bone growth stimulating devices and orthobiologics in healing nonunion fractures. The SOW specified that ECRI perform a narrative review of background information and surgical therapy and a systematic review of bone growth stimulating devices and orthobiologics. In commissioning this report, AHRQ, in consultation with CMS and ECRI, developed six Key Questions to be addressed. These questions are as follows:

1. How is a nonunion fracture diagnosed?
2. What are the risk factors for developing a nonunion fracture?
3. What are the current standards of care for nonunion fractures?
  a. What supportive measures are recommended?
  b. What surgical therapies are currently recommended for treatment of nonunion?
  c. What orthobiologics and external devices for stimulation of bone healing in nonunion fractures have been approved by the FDA and which have not been approved by the FDA?
4. What are the intermediate and patient-reported outcomes of treatment for nonunions, and how are they defined?
5. What is the evidence for variations in outcomes attributable to surgeon, procedure and institution characteristics?
6. What is the evidence for benefits and harms of bone growth stimulating devices and orthobiologics for treatment of nonunion fractures?

Nonunion fractures are defined by their failure to unite across the fracture gap in a prescribed time period.(30) The treatment options for nonunions are designed to restart the course of healing by enhancing the cellular processes that lead to fracture repair. Various surgical approaches, bone growth stimulating devices, and orthobiologics have been used separately or together in an effort to correct nonunion fractures and restore normal physical functioning. For Key Questions 1 through 5, this technology assessment addresses the diagnosis, risk factors, standard of care, important outcomes of treatment, and treatment outcomes for nonunion fractures by examining current reviews, clinical practice guidelines, orthopedic textbooks and selected clinical studies. For Key Question 6, this report systematically reviews clinical studies of bone growth stimulating devices and orthobiologics to assess their role in enhancing the healing process of nonunion fractures. We identified clinical studies relevant to Key Question 6 through electronic and manual searches of literature published between 1990 and 2005. In addition, we performed a supplemental search for the period 1975 to 1990 to expand the information pertinent to electrical bone growth stimulating devices. We also searched the most recent 2 years’ worth of meeting abstracts from the American Academy of Orthopedic Surgeons (AAOS), the Orthopedic Trauma Association (OTA) and the American Orthopedic Foot and Ankle Society (AOFAS) for new clinical studies of bone growth stimulating devices and orthobiologics.

This report is intended to highlight, where possible, the relevance of nonunion fracture treatments and outcomes to the Medicare population. Where available, outcome data reported for patients 65 years and older were separately abstracted from included clinical studies and entered into the evidence tables.

The findings of our assessment as they pertain to the six Key Questions are presented below.